# Methods

## Overview of Methods

Figure 1 provides an overview of the methods used in this project. Among CERs funded by AHRQ, we identified those that fulfilled our inclusion criteria. Within each of these CERs, we specified one outcome that fulfilled explicit criteria (the index outcome). For this pilot study we selected three CERs to examine in detail. RCTs examining the index outcome were then identified, and trial registries were searched for study registration and protocols. Focusing on RCTs that were listed in a trial registry, we then used registry information, along with the methods section of the publication, to determine the frequency of various types of SOR and SAR (Objective #1). For Objective #2, we examined prespecified predictors of the existence of SOR and SAR in RCTs. Lastly, using the ORBIT classification of SOR,3 we attempted to examine the inter-rater reliability of ORBIT and its validity, comparing SOR assessments using information contained within the publication to assessments of SOR using the additional information in trial registries (Objective #3).

Figure 1 Overview of report methodology

Abbreviations: AHRQ, Agency for Healthcare Quality and Research; CER, comparative effectiveness review; RCT, randomized controlled trial; SAR, selective analysis reporting; SOR, selective outcome reporting.

Overview of methods. Among CERs funded by the Agency for Healthcare Quality and Research (AHRQ), we identified those that fulfilled our inclusion criteria. Within each CER we then specified one outcome that fulfilled explicit criteria (the “index” outcome). RCTs examining the index outcome were then identified, and trial registries were searched for study registration and protocols. Focusing on RCTs that were listed in a trial registry, we then used registry information, along with the methods section of the publication and judgment about what outcomes should have been reported in a given study, to determine the frequency of SOR and SAR (Objective #1). For Objective #2, we examined prespecified predictors of the existence of SOR and SAR in RCTs. Lastly, using the ORBIT classification2 of SOR, we attempted to examine the inter-rater reliability of ORBIT and its validity, comparing SOR assessments using information contained within the publication (as ORBIT was intended) to assessments of SOR using the additional information in trial registries (Objective #3).

## Selection of the Cohort of Comparative Effectiveness Reviews

To explore SOR and SAR, we selected a cohort of CERs that fulfilled the criteria outlined in Table 2. We desired a cohort that was relevant to the AHRQ Effective Health Care Program, was feasible to examine with the resources allocated to this project, would provide results applicable to future AHRQ CERs, would contribute to the existing methodological literature on SOR and SAR, and would facilitate the development of specific guidance on the detection and implications of SOR and SAR for systematic reviewers in the Evidence-based Practice Center (EPC) Program. Of the 26 currently published CERs, 15 fulfilled these inclusion criteria (Table 3).

Table 2 Inclusion criteria for the AHRQ-funded systematic reviews examined in this report

General Criteria | Specific Criteria | Rationale | Number of Reports Fulfilling the Inclusion Criteria^a^
Type of review | Comparative effectiveness review | Reviews of comparative effectiveness are used for clinical and public health decision-making, thus understanding SOR and SAR for this type of systematic review is important. Technical briefs were excluded as they examine devices or diagnostic tests and include a very small number of RCTs. | 26
Review status | Final | Final reports were examined in order to avoid reports that may be revised in the near future, and to include reports that have been reviewed and incorporated input from peer reviewers, public comments, and the AHRQ Associate Editor. | 25
Focus of the CER | The focus must be pharmacotherapy with drug-drug or drug-placebo comparators. | Methodology of drug reviews is more advanced in general than reviews of devices, procedures, prognosis, diagnosis, or epidemiology. RCTs are likely to be included, and some sources of clinical and methodological heterogeneity may be minimized by examining only drug interventions. | 15
Design of included studies | The CER must contain 1 or more RCTs. | Only RCTs were examined as we sought to identify study registration and studies with other designs are much less likely to be registered. | 15
Outcomes | The CER must examine benefits. | Benefit outcomes may be more likely to be delineated in a trial registry than are specific harms. SOR of harms is also an important issue, but resource constraints did not permit us to explore harms in this project. | 15

Abbreviations: AHRQ, Agency for Healthcare Research and quality; CERs, comparative effectiveness reviews; NA, not applicable; RCT, randomized controlled trial; SAR, selective outcome reporting; SOR, selective outcome reporting.

a Reports were identified on April 12, 2011; the number of AHRQ CERs changes as additional reports are published. On that date, there were 26 CERs available on the AHRQ Website.

Table 3 Index outcome for each comparative effectiveness review

Comparative Effectiveness Review | Index Outcome | Number of RCTs^b^
1. Oral Diabetes Medications for Adults with Type 2 Diabetes. An Update19 a | A1c | 24
2. Effectiveness of Recombinant Human Growth Hormone (rhGH) in the Treatment of Patients With Cystic Fibrosis20 | Pulmonary function testing, including both forced expiratory volume in one second (FEV1) and forced vital capacity (FVC) | 1
3. Comparative Effectiveness of In-Hospital Use of Recombinant Factor VIIa for Off-Label Indications vs. Usual Care21 | Mortality | 4
4. Comparative Effectiveness of Angiotensin Converting Enzyme Inhibitors or Angiotensin II Receptor Blockers Added to Standard Medical Therapy for Treating Stable Ischemic Heart Disease22 | Mortality | 1
5. Comparative Effectiveness of Medications To Reduce Risk of Primary Breast Cancer in Women23 | Invasive and non-invasive breast cancer | 5
6. Comparative Effectiveness of Lipid-Modifying Agents24 a | All-cause mortality | 14
7. Comparative Effectiveness, Safety, and Indications of Insulin Analogues in Premixed Formulations for Adults With Type 2 Diabetes25 | A1c | 11
8. Comparative Effectiveness of Treatments To Prevent Fractures in Men and Women With Low Bone Density or Osteoporosis26 a | Fracture reduction, including both vertebral and extremity/hip/etc | 12
9. Comparative Effectiveness of Drug Therapy for Rheumatoid Arthritis and Psoriatic Arthritis in Adults27 | American College of Rheumatology 50 | 1
10. Comparative Effectiveness of Angiotensin-Converting Enzyme Inhibitors (ACEIs) and Angiotensin II Receptor Antagonists (ARBs) for Treating Essential Hypertension28 | Blood pressure control | 2
11. Comparative Effectiveness of Second-Generation Antidepressants in the Pharmacologic Treatment of Adult Depression29 | Response in treating depressive symptoms (according to various depression rating scales) | 0
12. Efficacy and Comparative Effectiveness of Off-Label Use of Atypical Antipsychotics30 | Obsessive-compulsive disorder: Yale-Brown Obsessive-Compulsive Scale | 1
13. Comparative Effectiveness and Safety of Analgesics for Osteoarthritis31 | Pain relief | 0
14. Comparative Effectiveness of Epoetin and Darbepoetin for Managing Anemia in Patients Undergoing Cancer Treatment32 | Hemoglobin levels | 2
15. Comparative Effectiveness of Management Strategies for Gastroesophageal Reflux Disease33 | Complete symptom relief at 4 and 8 weeks; time to complete resolution of symptoms | 1

Abbreviations: A1c, hemoglobin A1c; RCTs, randomized controlled trials.

a Comparative Effectiveness Reviews selected for further evaluation of SOR and SAR.

b Number of RCTs that reported the index outcome, were published in or after 2005, and which were registered.

## Identification of an Index Outcome for Each Included Comparative Effectiveness Review

We next identified a single effectiveness or efficacy outcome for each of the 15 CERs according to the criteria in Figure 2. Where available, the primary outcome of the CER was used as the index outcome for that CER. More commonly, the CER did not specify a primary outcome and two authors of this methods report independently selected one outcome as the index outcome based on the prespecified criteria. When differences between the two authors occurred, consensus was achieved through discussion.

Figure 2 Process for identifying an index outcome within each included comparative effectiveness review

Abbreviations: CER, comparative effectiveness review; MA, meta-analysis; RCTs, randomized controlled trials; SOR, selective outcome reporting.

Flow diagram depicting our process for identifying a single, index outcome within each included CER. We identified a single effectiveness or efficacy outcome for each CER according to the criteria in Figure 2. This outcome was either explicitly stated to be the primary outcome of the CER, or, more commonly, when the review did not specify, two authors of this methods report independently selected one outcome based on prespecified criteria. When differences between the two authors occurred, consensus was achieved through discussion. The prespecified criteria for the index outcome included 1) consistent measurement techniques and scale because it would be impossible to compare outcomes measured in different ways across studies and to attribute missing information to SOR or SAR rather than to differences in measurement approach. 2) We also selected outcomes for which a meta-analysis was presented in the CER as initially we planned to compare pooled estimates in the CER to estimates using imputation for missing outcomes (Objective #3). 3) There must be one or more trials published in or after 2005, when trial registries became more widely used. If the primary outcome designated in the CER fulfilled these criteria, it was selected as our index outcome. If the primary outcome in the CER did not fulfill these criteria, then we examined all outcomes of benefit listed in the key questions in the CER. We then selected an index outcome based on the following criteria: 1) the outcome was one of benefit; 2) it had a standardized measurement technique; 3) it had a meta-analysis in the CER; 4) there was one or more RCTs published in 2005 or later reporting that outcome; and 5) it is a patient-important health outcome. If several outcomes fulfilled these criteria, we selected the one with the largest number RCTs fulfilling the criteria.

The index outcome selected for each CER must be one that is consistently measured using the same technique and measurement scale because it would be impossible to compare outcomes measured in different ways across studies and to attribute missing information to SOR or SAR rather than to differences in measurement approach. We also selected outcomes for which a meta-analysis was presented in the CER as initially we planned to compare pooled estimates in the CER with estimates using imputation for missing outcomes (Objective #3).

We specified our index outcome at the level of a specific measurement (e.g., hemoglobin A1c [A1c]). We did not specify the metric (e.g., change from baseline) or the method of aggregation (e.g., continuous or categorical such as proportion of persons with A1c <7.0 percent). Thus our index outcomes were specified at level 2 (specific measurement) in the categorization proposed by Zarin and colleagues.34 We defined our index outcome with this level of specificity in order to explore the prevalence of changes in specification of outcomes within publications and between registry information and trial publications. For example, for the CER on oral hypoglycemic agents, we specified “A1c” as our index outcome and then looked for changes in followup intervals or changes from a continuous to a categorical variable, among others, that might represent SOR or SAR.

We refer to the selected outcome from each CER as the “index outcome” for that CER. We selected this term to differentiate it from the primary outcome of the report, if such was identified, and from the primary outcomes delineated in studies included within each CER.

One of the criteria that we used to select the index outcome for each CER was the number of trials included in the CER that reported the outcome, as described below (“Identification of randomized trials reporting the index outcome within each CER”). Thus the process of identifying an index outcome was an iterative one, where several potential outcomes might have been examined for a CER, and the number of RCTs determined for each of the potential index outcomes.

The index outcome for each of the 15 CERs in our cohort is indicated in Table 3.

Flow diagram depicting our process for identifying a single, index outcome within each included CER. Bullet points delineate the criteria for selecting an outcome for each CER.

## Identification of Randomized Trials Reporting the Index Outcome Within Each Comparative Effectiveness Review

After identifying the index outcome for each of the CERs, we then examined the CER for a list of included RCTs that reported any data on the index outcome. We reviewed all text, tables, and appendices for relevant trials.

We did not review lists of excluded studies, nor did we examine all trials included in the CER. Our approach limited our ability to detect certain types of SOR: we did not examine trials which omitted an outcome completely because those studies would not have been included in the CER for that outcome.

Our approach to identifying trials has important similarities to, and differences from, that described by Kirkham and colleagues in the ORBIT study.3 Like the ORBIT study, we started with a cohort of systematic reviews, from which we identified included trials. We confined our examination to trials that reported (at least partially), the index outcome. In contrast, ORBIT also examined trials that were included in a review even though they did not report the index outcome. In addition, the ORBIT team examined lists of excluded studies, looking for any potential SOR or SAR. The broader approach to study inclusion taken in the ORBIT study enabled their team to examine types of SOR where the outcome was not reported in the trial (ORBIT classes E, F, G and H; see Table 1). In our study, we did not examine trials that did not report in some way our index outcome.

Similar to the ORBIT study, we did not include trials that were not included in the CER but which may have reported the outcome of interest. In other words, we did not search trial registries or other sources for entire studies that were missing.

Table 3 lists the index outcome that we selected for each of the 15 CERs and the number of RCTs for each index outcome.

## Selection of Specific Comparative Effectiveness Reviews for This Pilot Study

In order to have a reasonable number of trials to examine the frequency and predictors of SOR and SAR, we selected the three CERs with the largest number of trials examining each of the three index outcomes.19, 24, 26 Resource constraints did not permit us to examine all identified CERs in this exploratory work.

We piloted our methods using the published report “Oral Diabetes Medications for Adults with Type 2 Diabetes. An Update” by Bennett and colleagues from the Johns Hopkins EPC.19 We selected this report because: (1) it was published recently (March, 2011) and therefore likely used current AHRQ methods; (2) diabetes mellitus has a high burden of illness; and (3) this review included a large number of RCTs (n=24 which were published after 2005 and that were listed in a registry) reporting on an outcome that has relatively standardized measurement techniques (A1c).

After developing and piloting our methods on the report on oral diabetes medications, we examined two other CERs.24, 26 These two CERs contained the largest number of RCTs for the index outcome and we wanted to achieve a reasonable cohort of trials for each of the three CERs. Mortality was chosen for the CER on lipid agents24 because there was a meta-analysis of that outcome in the report, and we wanted to focus on a patient-important, objective health outcome. We had planned to examine mortality as an outcome of benefit in this report; however RCTs reporting mortality always considered it an adverse event. We proceeded with an examination of this outcome anyway as our work was well underway when it became clear how mortality was handled in our included studies. For the CER on medications for fracture prevention in women with low bone density,26 we selected fractures as our “index” outcome because it is a patient-important, objective outcome, and was meta-analyzed in the CER.

A1c, mortality, and fractures thus provided us with a diverse set of outcomes and a cohort of 40 RCTs with which to explore how trial registries might contribute to the assessment of SOR and SAR in CERs.

## Identification of Trial Registration for Randomized Controlled Trials Reporting the Index Outcome

In order to identify SOR and SAR for the index outcome in our cohort of CERs and RCTs, we looked for trial registration, in other words, the public listing of an agreed-upon set of information about the design, conduct, and administration of a clinical trial.18 We focused on registries as a source of information for assessing SOR and SAR in order to develop guidance for the AHRQ EPC program on using registries for this purpose. We were aware of the potential limitations of registries for this purpose, and our goal was to explore the uses and limitations in order to inform guidance on this tool for assessing SOR and SAR.

Through discussion among our workgroup members, we devised an approach for identifying trial registration that optimized the sensitivity of our search (minimized missing registrations), but was still feasible given the available resources. Our approach is outlined in Figure 3, and discussed in detail below.

Figure 3 The process for identifying trial registration for each randomized controlled trial

Abbreviations: ICTRP, International Clinical Trials Registry Platform; PDF, portable document format; WHO, World Health Organization.

We searched the pdf of each trial publication for the terms “regist”, “clinical” and “trial” and also scanned the publication for a clinical trial registry number. If this number was identified, then we searched the relevant registry for the trial. If the publication did not contain a registry number, we then searched for registration using the advanced search tool within ICTRP. We used the study funder, country or countries where subject recruitment took place, and the generic names of the intervention and comparator drugs. We also changed the default setting for “recruitment status” to “all”. If this approach did not reveal the study of interest, we then searched on the study drug name only (generic and brand names) as we encountered instances where this less restrictive search identified relevant registrations when the more specific search did not. This process of searching for trial registrations was repeated for all studies without an identified protocol by a second, independent searcher. If we still did not identify a study registration, we then contacted the corresponding author indicated in the trial publication by e-mail, and asked if the study was registered, and if so, what the trial registration number was.

We confined our search for trial registration to studies published from January, 2005 forward because of the effective date of the International Committee of Medical Journal Editors (ICMJE) requirement for registration of published trials (July, 2005). Although ClinicalTrials.gov went online in February, 2000,^35^ registration was infrequent initially, and we wanted to focus our search efforts on a cohort of RCTs with a reasonable likelihood of registration. In addition, Zarin and colleagues36 reported that the quality and completeness of trial records improved since October, 2005.

We searched only the International Clinical Trials Registry Platform (ICTRP) for trial registration and protocols, as this platform encompasses ClinicalTrials.gov and a number of other registries, as noted above, and is updated regularly. If an RCT provided information on trial registration, particularly the National Clinical Trials number for ClinicalTrials.gov, we were able to quickly identify the study within ICTRP. Frequently, however, study publications provided no indication that the study was listed in a registry encompassed by ICTRP. If there was no indication of trial registration in the publication, we then searched for registration using the advanced search tool within ICTRP. We used the study funder, country or countries where subject recruitment took place, and the generic names of the intervention and comparator drugs. If this approach did not reveal the study registration, we then searched on the study drug name only (generic and brand names) as we encountered instances where this less restrictive search identified relevant registrations when the more specific search did not.

This process of searching for trial registrations was repeated for all studies for which we did not initially identify a trial registration by a second, independent searcher. If we still did not identify a study registration, we then contacted the corresponding author indicated in the trial publication via email, and asked if the study was registered, and if so, what the trial registration number was. For all studies with registration in ICTRP, we looked for results within the relevant registry.

## Data Abstraction

Data from the primary publication, and any companion papers cited in the CER, as well as information from the trial registration were abstracted into a standardized template in Excel (Microsoft Office Excel 2007, Microsoft, Redmond, WA). This template was piloted by study staff at Oregon Health & Science University and by members of the workgroup, using the CER on oral hypoglycemic agents.19 The template was revised as needed during the pilot phase. Abstracted data were reviewed by a second team member to ensure accuracy. Abstracted data included information from the publication (author affiliations and disclosures, study funder, interventions, relevant outcomes, analytic approach, and analysis set) and registry (dates of registration and recruitment, proposed primary and secondary outcomes and any changes among those, and relevant results [if available]).

### Exploration of the Timing of Trial Registration and Changes in Outcomes in the Registry

We compared the time of trial registration to the stages of research, including subject recruitment, study completion, and publication in order to examine how frequently studies were registered after subject recruitment started. In particular, we were interested in the frequency of registration late in the research process, such as at the time of publication.

We also examined the timing of changes in the index outcome within the trial registry. Ideally study outcomes are specified at finalization of the study protocol and prior to subject recruitment and are not subsequently changed. If an outcome did change in any way (e.g., timing of followup, continuous to categorical outcome), a rationale should have been provided in the registry, although this is not currently required in ClinicalTrials.gov.

### Identification of Selective Outcome Reporting and Selective Analysis Reporting

To determine the proportion of trials with SOR and/or SAR within a CER, we created a matrix of all the outcomes related to the designated index outcome. This approach was similar to that used by Kirkham and colleagues.3 Each row in the matrix represented an RCT that had an identifiable trial registration, and each column contained different approaches to presenting and/or measuring the index outcome across the included RCTs and trial registration information. Specifically, each column in the matrix contained outcomes which were:

1. mentioned in the methods section of the publication;
2. reported in the results section of the publication (including outcomes reported in different ways (e.g., categorical [with various definitions of categories] or continuous); or
3. reported in the trial registry (either registration information or results).

This exploration and data display enabled us to depict the universe of potential approaches to specifying and presenting the index outcome for each CER, and to identify outcomes reported in either the trial report or in the trial registry, but not both. We did not seek content expert input to discern other relevant outcomes as we felt that the list of outcomes that we identified in the CER and trial registry adequately represented the universe of potential outcomes.

We used a similar approach to identify SAR. We noted the planned analyses in the methods section of publications and any information in the trial registry, and compared those to the reported analyses within and across trials. We did not expect that information in trial registries would be as detailed for SAR as for SOR, nonetheless, we sought information on SAR in a similar manner. We did not include information that was provided in the results section of the registry (when available) on how analyses had been performed, as that information was added to the registry with the results, and thus might reflect post hoc decisions and not prespecified approaches.

Since this work was exploratory, we did not develop a specific list of discrepant or altered analyses that we would consider as SAR. Rather, we sought to describe any change in analytic approach between the methods section of the publication or the registry summary information, and results reported in the publication. SAR includes, for example, selective reporting of data on subgroups, presentation of adjusted compared with unadjusted analyses, selection of different analytic sets (e.g., as-treated vs. intention-to-treat), selective approaches to the handling of missing data, choosing to analyze continuously measured variables categorically or changing measurement scales, and choice of cut-point values to define categorical variables.4 We sought cases where there was a change from the originally specified analytic approach, rather than situations where analyses appropriately tested different models to achieve optimal fit to the data.

In our exploration of SOR and SAR within each included trial, we started with the definition of SOR delineated by Kirkham and colleagues.3 We soon noted, however, that there were many additional facets of potential reporting biases related to selection of outcomes and analyses that were not encompassed by this definition. We therefore developed a broad set of “judgments” that represent the types of SOR and SAR that we were observing. These judgments were based on the information that was used to determine if SOR or SAR likely exist (Table 4).

Table 4 Types of selective outcome reporting and selective analysis reporting classified by the approach used for detection

Judgment #1 | Judgment #2 | Judgment #3^a^ | Comments
Publication methods vs. publication results | Trial registry summary vs. publication results | Trial registry results vs. publication
NA | NA | Differences in the numerical values reported in the publication and the registry | ---
Change in primary and/or secondary outcome designation for the index outcome between methods and results | Change in primary and/or secondary outcome designation for the index outcome between the registry (current outcome) and the publication | NA | “Yes” if there was a switch in primary vs. secondary designation of the index outcome between the registry and the publication.
Change in the index outcome between methods and results | Change in the index outcome between registry and publication | NA | This includes a change in the specificity of the description of the outcome between the registry and the publication (e.g., outcome listed as “glycemic control” in the registry and “change in A1c” in the publication.
Outcome listed in methods but not reported in results | Outcome listed in the registry but NR in the publication | Outcomes reported in the registry results but not in the publication | Typical SOR per Kirkham and colleagues3
Outcome in methods inadequately reported in results | Outcome listed in the registry inadequately reported in publication | Outcomes reported in the registry results but not adequately reported in the publication | Typical SOR per Kirkham and colleagues3
Change in followup interval between registry and publication | Change in followup interval between registry and publication | Change in followup interval between registry and publication | Includes any discrepancy between the followup interval specified in the registry and in the publication.
Outcome reported in results but not reported in methods | Outcome reported in publication but not listed in the registry | Outcomes reported in the publication but not in the registry results | Type of SOR that differs from the classes depicted by Kirkham and colleagues3
Change in analyses between methods and results | Change in analyses between registry and publication | Change in analyses between registry and publication | ---
Subgroups reported in results that were not described in the methods section or vice versa | Subgroup specified in the registry but NR in the publication(s) or vice versa | Subgroup reported in the registry but NR in the publication, or vice versa. | ---
Summary: judgment #1: SOR and/or SAR are deemed to be present if there are discrepancies in description of the index outcome between the publication methods and results section. | Summary: judgment #2: SOR and/or SAR are deemed to be present if there are discrepancies in description for the index outcome between the trial registry summary information and the results section of the publication. | Summary: judgment #3: SOR and/or SAR are deemed to be present if there are discrepancies in the results presented for the index outcome between the trial registry results and the results presented in the publication. This includes both the publication of a subset of the results in the registry and the publication of additional results not presented in the registry. | ---

Abbreviations: A1c, hemoglobin A1c; NA, not applicable; NR, not reported; SAR, selective analysis reporting; SOR, selective outcome reporting.

a Judgment #3 is not applicable if there are no results in the registry or no differences in results between the publication and registry.

Judgment #1 compared the methods and results sections of the trial publication. Judgment #2 compared the “current outcome” listed in the summary information in the registry to the results reported in the publication for that trial. Judgment #3 compared the results reported in the registry to the results reported in the publication. Discrepancies in one of these comparisons constituted an assessment of “yes” for that judgment. Each judgment was made independently by two authors (SLN and HKH), and consensus was achieved through discussion.

Our approach to identifying SOR and SAR focused on discrepancies between the methods and results section of the trial publication, and between information provided in trial registries and the publication. There are several reasons why such discrepancies might occur in addition to SOR and SAR, such as random error or the non-reporting of results for reasons other than the nature and direction of the outcomes. In this pilot study we chose to examine discrepancies, and we did not try and determine the reason for the discrepancies. Nor did we try and determine the risk of bias associated with each discrepancy. Our approach resembled that of the ORBIT study,3 which focused on discrepancies within the publication (as well as between clinical judgment and the publication).

In Table 5 we provide a more detailed classification system for SOR and SAR, including the ORBIT categories as well as the type of SOR where outcomes were added that were not prespecified. We also outline the sources for the studies that contribute to the assessment of a given type of SOR and the information that was examined for discrepancies that might represent SOR.

Table 5 Types of selective outcome reporting and their relationship to ORBIT classes and to risk of bias

Description of the Outcome | Source of Trials Used To Examine This Type of Outcome | ORBIT Class | Our Assessment | Full, Partial, or No Reporting | Source of Discrepancy Used To Determine if SOR is Present | Risk of Bias^a^ | Comment
Outcome fully reported in the results of the publication | Studies included in the review | NA | Judgment #1,2,3 all negative (no SOR) | Full | Between publication methods and publication results, and between other available information (e.g., trial protocol, registry, or clinical judgment) and study publication | None | No SOR (outcome prespecified and fully reported)
Outcome fully reported in the results of the publication | Studies included in the review | NA | One or more of judgments #1,2,3 are positive (outcomes added that were not prespecified) | Full | Between publication methods and publication results, or between other available information (e.g., trial protocol, registry, clinical judgment) and study publication | High | “Data dredging”
Clear that the outcome was measured and analyzed | Studies included in the review | A, B, C | Judgment #1 positive | Partial | Between publication methods and publication results | High or low (per Kirkham)3 | Outcome is partially reported in the publication
Clear that the outcome was measured and analyzed | Studies included in the review | D | Judgment #1 positive | No | Between publication methods and publication results | High (per Kirkham)3 | The whole outcome is missing or there is a difference in the specific metric for the outcome
Clear that the outcome was measured, unclear whether it was analyzed | Studies included in the review for the index outcome | E, F | Judgment #1 positive | No | Between publication methods and publication results | High or low (per Kirkham)3 | The whole outcome is missing or there is a difference in the specific metric for the outcome
Clear that the outcome was measured, unclear whether it was analyzed | Studies included in the review for the index outcome or studies not identified for the review | NA | Judgment #2 positive | No | Between trial registry summary and publication results | High or low | The whole outcome is missing or there is a difference in the specific metric for the outcome
Clear that the outcome was measured, unclear whether it was analyzed | Studies included in the review for the index outcome or studies not identified for the review | NA | Judgment #3 positive | No | Between trial registry results and publication results | High or low | The whole outcome is missing or there is a difference in the specific metric for the outcome
Unclear whether the outcome was measured | Studies included in the review for other outcomes than the index outcome, or studies not identified for the review | G, H | NA | No | Between clinical judgment and the publication results | High or low (per Kirkham)3 | The whole outcome is missing or there is a difference in the specific metric for the outcome
Clear that the outcome was measured, unclear whether it was analyzed | Studies included in the review for the index outcome | E, F | Judgment #1 positive | No | Between publication methods and publication results | High or low (per Kirkham)3 | The whole outcome is missing or there is a difference in the specific metric for the outcome
Clear that the outcome was measured, unclear whether it was analyzed | Studies included in the review for the index outcome or studies not identified for the review | NA | Judgment #2 positive | No | Between trial registry summary and publication results | High or low | The whole outcome is missing or there is a difference in the specific metric for the outcome
Clear that the outcome was measured, unclear whether it was analyzed | Studies included in the review for the index outcome or studies not identified for the review | NA | Judgment #3 positive | No | Between trial registry results and publication results | High or low | The whole outcome is missing or there is a difference in the specific metric for the outcome
Unclear whether the outcome was measured | Studies included in the review for other outcomes than the index outcome, or studies not identified for the review | G, H | NA | No | Between clinical judgment and the publication results | High or low (per Kirkham)3 | The whole outcome is missing or there is a difference in the specific metric for the outcome
Clear that the outcome was not measured | Studies included in the review | I | NA | No | No discrepancy | No risk (per Kirkham)3 | Bias may have also been introduced at the design phase of the study; this is not captured by SOR because the nonreporting due to study design is not dependent on the results
Clear that the outcome was measured, unclear whether it was analyzed | Studies included in the review for the index outcome | E, F | Judgment #1 positive | No | Between publication methods and publication results | High or low (per Kirkham)3 | The whole outcome is missing or there is a difference in the specific metric for the outcome
Clear that the outcome was measured, unclear whether it was analyzed | Studies included in the review for the index outcome or studies not identified for the review | NA | Judgment #2 positive | No | Between trial registry summary and publication results | High or low | The whole outcome is missing or there is a difference in the specific metric for the outcome
Clear that the outcome was measured, unclear whether it was analyzed | Studies included in the review for the index outcome or studies not identified for the review | NA | Judgment #3 positive | No | Between trial registry results and publication results | High or low | The whole outcome is missing or there is a difference in the specific metric for the outcome
Unclear whether the outcome was measured | Studies included in the review for other outcomes than the index outcome, or studies not identified for the review | G, H | NA | No | Between clinical judgment and the publication results | High or low (per Kirkham)3 | The whole outcome is missing or there is a difference in the specific metric for the outcome
The study was not published and thus the outcome is not available to the systematic reviewer | Unpublished data (e.g., protocols, trial registries) | NA | NA | No | Published data with no corresponding publication | High | Known as publication bias; not examined in this report

Abbreviations: NA, not applicable; ORBIT, Outcome Reporting Bias in Trials study (Kirkham 2010)3; SOR, selective outcome reporting.

a Risk of bias is based either on the assessment of Kirkham and colleagues3 as indicated, or on our subjective assessment of the risk.

We made the assumption that information in the trial registries was correct as we looked for discrepancies between the registry information and the publication. Issues with the quality of data entry in ClinicalTrials.gov have been raised in the past, although these have focused only on the quality of the entries for the primary outcome measures, particularly their specificity.36

## Predictors of Selective Outcome Reporting and Selective Analysis Reporting

We explored potential predictors of SOR and SAR, using prespecified, study-level, independent variables. Since this is an exploratory analysis where there is essentially no existing empirical evidence, we selected a variety of diverse predictors based on our hypotheses. First, we predicted that funding and other conflicts of interest on the part of the funder and authors might influence the frequency of reporting biases. We based this prediction on existing data that suggest that financial and other conflicts of interest can affect the data presented and the conclusions in primary studies.37–40 Second, we sought to examine the possibility that SOR and SAR might vary with the characteristics of the registry and the timing of trial registration. We theorized that the level of detail required in a registry and the timing of registration (ideally before subject recruitment starts) might affect the frequency of SOR. Third, we explored the situation where trial authors changed outcomes in the registry between initial registration and the last update of outcomes in the registry. Since this was not captured in our definitions of SOR and SAR, we hypothesized that such changes might relate to the selection of outcomes based on the results and might therefore correlate SOR and SAR. We therefore examined the following independent variables:

1. Characteristics of the funder and authors
  a. One or more study funders or sponsors manufactured one or more of the intervention drugs (categorical variable, yes/no).
  b. One or more authors were employees of a company making one of the intervention drugs (categorical variable, yes/no; percentage of authors who were employed by the company making one of the intervention drugs (proportions).
  c. Assistance in writing the manuscript was provided by study funder (categorical yes/no). When the source of funding for authorship was unclear or not reported, the response was considered “no.”
2. Trial registration
  a. Registry in which study was registered (categorical variable, ClinicalTrials.gov vs. other registry).
  b. Timing of trial registration with respect to first subject recruitment (categorical variable, before or the same month, vs. after or unclear).
  c. Studies with results compared with studies with no results in the registry. Here we only examined judgments #1 (publication methods vs. results) and #2 (registry summary vs. publication results) as the dependent variable. (Note that only ClinicalTrials.gov provided results.)
3. Changes in the index outcome within the registry
  a. Studies that changed the index outcome between “original” and “current” within the trial registry (categorical variable, yes/no). The following were considered “yes” responses:
    i. change in designation between primary and secondary outcome;
    ii. change in specificity (e.g., “glycemic control” was the original outcome and “change in A1c between baseline and week 24” was the current outcome in the trial registry); or
    iii. addition of an outcome to the registry (e.g., “percentage of patients who achieved A1c < 7.0 percent at followup” was added to the registry where “change in A1c” was the only original A1c-related outcome).

We examined change in the index outcome (point #3, above) as a predictor of judgments #1, #2, and #3 (our definition of SOR), as changes between the “original” and “current” outcomes listed in trials registries were not part of our definition of SOR. Our criteria for SOR involved only a comparison of the “current” outcome listed in the registry to what was published in the publication (judgment #2: registry summary vs. publication results). Thus a change in outcome from “original” to “current” might be a predictor of SOR as we defined it. In other words, if trial authors made changes to the primary and secondary outcomes listed in the registry, we explored the correlation of such changes with SOR.

The dependent variables for this analysis were:

1. Presence of SOR or SAR detected by examining the publication only (“judgment #1”: publication methods vs. publication results).
2. Presence of SOR or SAR detected by comparing registry information to the results reported in the publication (“judgment #2”: registry summary vs. publication results).
3. Presence of SOR or SAR detected by comparing the results in the registry (if any) to the results reported in the publication (“judgment #3”: registry results vs. publication results).

We combined data from the reports on oral hypoglycemic agents19 and osteoporosis26 as we considered that the potential predictors of our judgments on SOR and SAR would likely be similar between the two reports. For the report on lipid modifying agents,24 the dependent outcomes for all RCTs were judged to have the same type of SOR, precluding statistical analysis to explore predictors.

In order to examine the relationships between the timing of initial study registration, specification of final primary and secondary outcomes, and publication, we explored the chronology of these events in detail by developing a timeline for each RCT for the CER on oral hypoglycemic agents,19 and osteoporosis26 based on information from both the study publication and the trial registry.

## Assessment of the Reliability and Validity of the ORBIT Classification of Selective Outcome Reporting

We initially proposed examining the inter-rater reliability and validity of the ORBIT classification system, in addition to the feasibility of its implementation. For our assessment of inter-rater reliability, each index outcome within each included RCT was classified by two independent assessors as fully reported, partially reported, or not reported, using the ORBIT categories A through F.3 The assessors (SLN and HKH), both coauthors on this report, have formal training in epidemiology, and are experienced in systematic review methods including the assessment of risk of bias in primary research studies. After documentation of the two independent assessments, the two assessors achieved consensus through discussion. The assessors initially piloted the ORBIT assessments by independently rating four included RCTs, followed by discussion and consensus on the ORBIT classification. For the RCTs that were not part of the training exercise, we planned to calculate a kappa statistic as well as percentage agreement between assessors for each of the nine ORBIT categories and overall.

We planned to assess the validity of the ORBIT classification system by comparing the ORBIT classification of SOR using the trial publication to the ORBIT classification achieved using additional information from the trial registry. We planned to examine the percentage agreement in the classification between these two approaches.

We examined one aspect of the feasibility of using ORBIT by recording the time in minutes it took each assessor to complete the ORBIT classification using the trial publication and registry information, and then the time it took to examine trial results in the registry (if any) and to make any further assessments of ORBIT.

## Data Syntheses and Analyses

This was an exploratory study, and so we selected a convenience sample of CERs and RCTs to examine, and no sample size calculations were performed. The three CERs that we examined involved different types of outcomes, so we described each of the three cohorts of RCTs separately.

Descriptive statistics were used to present our findings on SOR and SAR among the RCTs included in this study. In addition, we examined the association between potential predictors and the presence or absence of SOR or SAR as indicated by judgments #1, #2, and #3 as outlined above. Due to the small sample size, the association between the presence of SOR and SAR and study-level characteristics was explored using Fisher’s exact test and exact logistic regression. Since there was no significant difference between SOR and SAR in the two CERs (diabetes and fracture prevention), the analysis was first conducted by combining data from the diabetes and fracture studies to assess overall association. Then the analysis was conducted by examining RCTs in the two CERs separately to look at association for each individual CER.