# Peer Reviewers

Lisa Bero, Ph.D.

Professor

University of California, San Francisco

San Francisco, CA

An-Wen Chan M.D., D.Phil.

Assistant Professor

University of Toronto

Toronto, Canada

Davina Ghersi, M.P.H., Ph.D.

World Health Organization

Geneva, Switzerland

Yoon Loke, M.D., M.B.B.S.

Clinical Senior Lecturer

University of East Anglia

Norwich, U.K.

Erik von Elm, M.D., M.Sc.

University Hospitals of Lausanne

Institut of Social and Preventive Medicine

Lausanne, Switzerland

Paula Williamson, Ph.D.

Professor

University of Liverpool

Liverpool, U.K.

Deborah Zarin, M.D.

Director of ClinicialTrial.gov

National Library of Medicine

National Institutes of Health