# Acknowledgments

The authors gratefully acknowledge Thomas A. Trikalinos, M.D., Ph.D., Sasha Walia, M.P.A., Katie Reitel, B.A., and Leah Williams, B.S., for their technical contributions to this project.