# Discussion

Our work identifying and characterizing SOR and SAR in a small cohort of trials and using information from the study publication and the trial registry suggests that outcomes are frequently added to the results in publications that were not listed in the publication’s methods section or specified in trial registries. Types of SOR that correspond to those in the ORBIT classification system A through F were uncommon in our cohort. Trial registries indicated frequent changes in the outcomes listed in the study summary, with many of those changes occurring late in the research process. In addition, there was often inadequate specification of the initial outcomes, making it difficult to determine if there were significant differences in outcomes between the registry and publication. Neither the study publication nor the registry provided useful information for identifying SAR. In addition, exploration of trial registries was time consuming. The identification of trial registry numbers took multiple steps and trial registries did not have an optimal interface for exploring SOR or SAR.

Our work provides valuable experiences and lessons upon which to start building operational guidance for exploring SOR and SAR in trials and for incorporating those findings into systematic reviews.

## Strengths and Limitations of This Study

We explored SOR and SAR in a real-world cohort of RCTs included in AHRQ CERs. The challenges encountered and lessons learned contribute to knowledge directly applicable to future CERs supported by AHRQ and other sponsors and authors. We are not aware of published literature exploring the use of ORBIT, nor other attempts to examine the reliability and validity of this classification system. We purport that our suggestions for revisions of existing tools and our recommendations for future research may be applicable to work on reporting biases in biomedical studies, well beyond the cohort of trials and CERs examined in this report.

There are a number of limitations to our study. First, we examined only three CERs and 40 trials. Thus our findings may not be applicable to systematic reviews of other types of interventions and outcomes, and our findings on SOR and SAR at the trial level may not be generalizable to a wider variety of trials. Registration of studies of designs other than randomized trials is infrequent (observational studies constituted 15 percent of studies in ClinicalTrials.gov in January, 2007^36^) and the prevalence of SOR and SAR may exceed that for trials.44, 45 Thus, our findings are unlikely to be applicable to study designs other than RCTs. In addition, our small sample size of RCTs limited our power to detect significant predictors of SOR.

Second, we faced limitations inherent in trial registration: lack of registration of all trials after 2005 and infrequent registration prior to that year. Thus we could not examine complete cohorts of trials included in meta-analyses within CERs.

Third, studies listed in trials registries may not be representative of all trials published. Perhaps registered trials differ in important reporting and quality characteristics from trials that are not registered. If registered trials are of higher quality, they might have lower rates of SOR and SAR, and thus our cohort may underestimate the frequency of SOR and SAR across trials included in a CER, both registered and unregistered.

Fourth, information in various trial registries differed. Most importantly, more information was provided in ClinicalTrials.gov than in other registries for our cohort of trials. Thus all registered trials do not contain the same information and level of detail. For example, as far as we are aware, only ClinicalTrials.gov tracks all changes made to the registration information. Thus comparing and synthesizing the frequency of SOR and SAR across different registries is problematic.

Fifth, during the consensus process between the two assessors of SOR/SAR, our thinking and definitions of SOR/SAR evolved as each assessment brought nuances and new issues, making calculations of inter-rater reliability meaningless in this exploratory work. We were thus unable to calculate inter-rater reliability for ORBIT assessments as we had planned.

Lastly and most importantly, we did not examine studies excluded from CERs because they did not report data on our outcome of interest (“index outcome”). Such studies are excluded by authors of CERs prior to the synthesis phase of the systematic review, and we did not seek out such studies. We also did not look at other trials in each CER to see if they could have reported out index outcome (but did not). This latter approach was taken by Kirkham and colleagues,3 enabling them to identify ORBIT classes G and H. Such studies may have exhibited SOR leading to exclusion of the study from a CER, and thus our estimates would underestimate the frequency of SOR. Examination of all studies in each CER and of additional studies reporting on each intervention as identified through registries or FDA documents might lead to a more complete and accurate assessment of SOR for each index outcome. In addition, the conclusions in a CER are based on an assessment of multiple outcomes, both benefits and harms, and we only examined single outcome for each CER.

And finally, our study does not examine the broader issue of bias in study design and choice of outcomes based on anticipated findings by the trialists. This manipulation of study design is not technically SOR or SAR, which are defined in terms of the selective reporting of outcomes based on results. Efforts such as the Core Outcome Measures in Effectiveness Trials (COMET) Initiative46 are working to address this issue. Although such design issues are a critical source of bias affecting the internal validity of trials, they are beyond the scope of this report.

## Challenges Encountered Developing Our Study Protocol

The methodology of this project changed significantly as it proceeded. We had initially proposed exploring SOR and SAR in nonrandomized studies, to develop an ORBIT-like classification system for nonrandomized studies, and to quantify the effects of SOR/SAR on effect estimates in meta-analyses in CERs. These initial goals proved infeasible, however, and were changed after lengthy discussions among the coauthors of this report. In the absence of registry information or any other prespecified characteristics on nonrandomized studies, we did not feel that we were able to explore the frequency of SOR/SAR in these study designs. We felt that determination of SOR/SAR based purely on information in the publication would not be useful.

We therefore evolved our objectives to focus on RCTs, with an assessment of the proportion of trials included in CERs with SOR or SAR, determination of the inter-rater reliability of the ORBIT classification system, and an examination of ORBIT’s validity when used to assess trial publications (as the tool was intended) when compared with ORBIT assessment using trial registry information. ORBIT proved inadequate for our assessment of the types of SOR and SAR that we identified in included RCTs, and assessment of ORBIT’s inter-rater reliability and validity proved infeasible as discussed above.

We also explored quantifying the effect of SOR/SAR in RCTs by comparing the effect estimate from meta-analyses in CERs to estimates obtained using imputed data in studies with missing outcome data (i.e., SOR), using an approach such as that of Copas and Jackson.8 After discussion among the coauthors of this report, we decided that such analyses would not be useful in view of the multitude of assumptions made in such imputations, and the difficulty determining if SOR/SAR existed in individual studies. In addition, studies contributing to pooled estimates frequently included those published both before and after 2005. The former studies were rarely listed in trial registries and more recent studies were not always registered. The coauthors of this report felt that we should focus on describing SOR/SAR and exploring ORBIT, rather than on problematic quantitative estimates.

We had initially proposed examining SOR and SAR separately. The distinction between the two was often unclear, however. For example, an outcome such as A1c could be analyzed in several ways, including as a continuous measure (with absolute change in percent) or as categorical outcome with various thresholds defining the categories. These presentations of A1c could be considered different outcomes or different analyses. Thus the distinction between SOR and SAR is somewhat arbitrary.

## Challenges and Recommendations Regarding Methods and Available Tools for Exploring Selective Outcome Reporting and Selective Analysis Reporting

As a result of our exploration of SOR and SAR in a small cohort of RCTs and our use of trial registries to identify SOR/SAR and to assign an ORBIT class, we formulated a number of comments and suggestions on these tools and the potential approaches that systematic reviewers might use (Box 1). Our suggestions are intended to stimulate and provide a basis for future discussions that might ultimately lead to the development of explicit guidance for systematic reviewers.

Box 1 ORBIT: Challenges and limitations

#### Challenges using the ORBIT classification system

1. Difficulty making distinctions among the ORBIT categories
2. Problems determining if an exact p value could be determined from the data presented

#### Limitations of the ORBIT classification system

1. Scope and intended use: ORBIT was designed for use with the trial publication(s) only, and not for use with additional information such as that obtained from trial registries or protocols. We found that this additional information could rarely be applied to ORBIT categories.
2. ORBIT only addresses missing outcomes, i.e., those that the reader expects from reading the methods section or from clinical judgment. ORBIT does not include the addition of outcomes or analyses to results section that do not appear to have been specified a priori.

### ORBIT

#### Challenges and Limitations of the ORBIT Classification

We encountered a number of problems when we used ORBIT to assess included trials for SOR and SAR. First, we had difficulty making distinctions among ORBIT categories. Nine categories are a large number to have assessors consider with an adequate degree of reliability. Our team’s assessors had difficulty making the distinction between categories E and F, for example, which depends upon an assessment of why an outcome might have been measured but not reported. Second, in some studies it was difficult to determine if an exact p value could be determined from the data presented in the trial publication, particularly if the assessor did not have a statistical background. Kirkham and colleagues3 indicate that determination of the ORBIT class can use data calculated indirectly from the results (e.g., an exact p value calculated from the standard error of an estimate). With adjusted and between-group analyses it was sometimes unclear to the assessor whether an exact p value could be calculated without access to the underlying dataset.

The most important issues that we encountered with ORBIT were not with its implementation, but rather with the limited nature of its intended use and scope. ORBIT was designed for the assessment of SOR/SAR using information within the publication(s) plus clinical judgment.3 We assert, however, that the most important indicators of SOR and SAR are obtained from sources outside of the published report, such as trial registries or databases of research protocols. ORBIT does not incorporate this additional information. Our efforts to compare information in the trial registry, including results (if any), with the publication (judgments #2 and #3) were met with limited success because the most common situation was the addition of outcomes that were not prespecified, and ORBIT does not accommodate that type of SOR or SAR. Registry information could contribute to assessments of ORBIT classes G and H – when it was unclear in the publication if the outcome was measured, but we did not encounter G and H assessments because of our study design.

In addition, ORBIT only addresses missing or incomplete outcome reporting as it considers outcomes that the reader is led to believe will be in the results section - either because they are mentioned in the methods section, or clinical judgment or information from other studies suggests that an outcome should be reported. The far more frequent scenario in our experience, however, was the reporting of outcomes in publications that had not been mentioned either in the methods section of the publication or in the trial registry. ORBIT also does not include the frequent changes that appear to occur in the primary or secondary outcomes in a study: either when or how an outcome was measured, or the evolution of an outcome initially poorly specified (e.g., “glycemic control”) to one with specificity after subject recruitment had been completed. Such changes can only be identified by a careful review of the History of Changes in ClinicalTrials.gov. ORBIT also does not address the issue of the validity of study conclusions based on data reported in a given publication. Studies have been documented to present biased conclusions that correlate with the funders’ interests.37, 39, 40, 47

Perhaps most importantly, because ORBIT focuses exclusively on the study publication(s), poor writing can lead directly to the appearance of SOR and SAR, where the “selectively” reported outcome is missing simply because of an error or omission or because of constraints on the number of words in the publication. In this situation, apparent SOR and SAR might not lead to actual bias in reporting, if the selective reporting does not relate to the direction and statistical significance of the results. On the other hand, SOR and SAR (and the presence of outcome reporting bias) could be obscured by careful writing.

These limitations in the scope of ORBIT as a tool for assessing SOR/SAR are not criticisms of ORBIT per se, as it was not intended to address these additional types of selective reporting of outcomes and analyses. These limitations, however, point to the need for additional tools to identify and assess SOR/SAR in primary studies.

#### Recommendations for Future Research on the ORBIT Classification System

A new tool is needed for the assessment of SOR/SAR based on all available information, both within and beyond the study publication(s), including trial registries and protocols and unpublished data sources. Such a tool needs to have a limited number of categories and should be broadly applicable to a variety of study interventions and outcomes. This new instrument needs to incorporate both the selection of outcomes from those prespecified, and the addition of new outcomes that differ from those prespecified in the methods section or trial registry. The types of SOR/SAR incorporated in our judgments #2 and #3 (Table 3) may be a useful starting point for development of such a tool. Based on our experiences with the ORBIT classification system, we suggest that the number of categories be relatively small, and judgments based on undocumented information be removed (e.g., the distinction between ORBIT classes E and F, and G and H). Such a tool needs early evaluation, including both reliability and validity assessments.

At a later date, classification systems for nonrandomized studies need to be developed also. We recommend, however, that systems for RCTs be the initial focus for research, as trials are more uniform in design, more information is available in registries and other databases, and nonrandomized studies are often exploratory – purposefully without prespecification of all outcomes and analyses.

If ORBIT continues to be used, research is needed to determine the intra- and inter-rater reliability of the ORBIT classification system. To our knowledge, there are no reliability data on this instrument. A cohort of individuals with training and experience in the critical appraisal of trials should examine studies from a variety of subject fields and with a variety of index outcomes. Efficacy, effectiveness, and harms outcomes should be examined for SOR/SAR, as the frequency of SOR and SAR and the reliability of the ORBIT tool likely vary across types of outcomes.

In addition, the ORBIT classification system needs to be validated. Kirkham and coauthors3 performed a limited assessment of the accuracy of ORBIT classes G and H (unclear whether the outcome was measured or not) by comparing their designated class to information provided by the trialists. The sensitivity for predicting that the outcome had been measured was 92 percent and the specificity for predicting that the outcome had not been measured was 77 percent. This assessment of the accuracy of ORBIT was calculated based on a response rate from the trialists of 12 percent (65 of 538 author reports).

### Trial Registries

#### Problems Encountered Using Trial Registries

Trial registries are an important recent advancement in biomedical research, improving public knowledge about ongoing and completed trials, promoting access to research results, and delineating prespecified study methods. Study registries were not as useful as we had anticipated for identifying and characterizing SOR and SAR, however. The following comments focus on ClinicalTrials.gov, as that was the predominant registry that we encountered, other registries that we examined contained less information than did ClinicalTrials.gov, and only this registry contains results (Box 1).

The list of primary and secondary study outcomes on the summary page for each study in ClinicalTrials.gov often did not meet our needs or it was unclear how best to use the information that was provided. ClinicalTrials.gov indicates the “original” and “current” outcomes, both primary and secondary. This information can be used to quickly determine if there was a change in the primary and secondary outcomes and/or a change in an outcome’s designation as primary or secondary. This information was most useful when outcomes were fully specified in terms of how and when they were measured. Frequently, however, outcomes listed in the registry were inadequately specified, particularly the original outcome, thus we could not determine if there was a significant change between the original prespecification and the published outcomes. For example, “A1c” might be specified as the original outcome in the registry, and the current outcome listed as “change in A1c (percent) from baseline to 26 weeks.” Although we classified this as a change in the index outcome and considered it potential SOR, the trialists’ original outcomes and their motives for the change were unclear.

In addition, the summary page with the “original” and “current” outcomes was only part of the story on changes in specified outcomes over the course of a trial. Additional information could be found by clicking on the “History of Changes” link, where various aspects of study outcomes could change numerous times during the course of the trial, but only the “original” and “current” outcomes are captured on the registry summary page. It is very time consuming to review the “History of Changes,” and difficult to determine if changes represented potential SOR. Although one might suspect SOR/SAR based on the timing of changes, it was not possible to determine if the trialists were purposefully manipulating reported outcomes after they had performed analyses and identified outcomes that they considered favorable.

Safety outcomes appeared to be less precisely specified in the registry, although our experiences were confined to the outcome of mortality for the CER on lipid agents.24 In reviewing the other two CERs, we rarely encountered any specification of safety outcomes, although we did not quantify those findings.

The study information sections of trial registries provided no information informing SAR for any of our included studies. No trial registration provided any information on analyses set, subgroups, proposed analyses, or covariates. The registry results frequently provided such information, but since that information was entered after analyses were completed, it was not prespecified and thus did not inform our assessment of SAR.

Registry results, when available, did provide useful information that could be compared to the trial publication. In the majority of RCTs with available results, however, the registry results were less complete than the publication for our index outcome. In other words, additional analyses and results were published that were not presented in the registry, while we rarely encountered the situation where the registry results were more complete. We consider the addition of new outcomes and analyses an important type of SOR/SAR, because they may reflect results favorable to the authors and/or study funders.

Frequently results were not presented in the registry (53 percent of our studies overall). There are legitimate reasons why a trial might not have results posted in a registry.48 ClinicalTrials.gov, however, does not provide a reason when trial results are not posted in the registry, and only the situation of an ongoing study can be deduced from the registry.

For each included RCT registered with ClinicalTrials.gov, we examined the “History of Changes” page of the registry for relevant changes and encountered a number of challenges. First, the vast majority of changes were of no relevance to our exploration of SOR and SAR, and it was difficult to efficiently identify potentially relevant changes among the plethora of information. The “History of Changes” contains spelling and punctuation corrections, the addition of abbreviations, the addition of citations for publication derived from the trial, the addition of study results, and changes in outcomes, among many other types of changes. Although there are categories of changes in ClinicalTrials.gov, including protocol, recruitment status, location/contact, administrative, and miscellaneous, protocol changes were often combined with administrative changes if they occurred on the same date. Thus the user often had to review irrelevant information when looking for significant protocol changes.

Second, in addition to the amount of information that had to be reviewed, the format for presentation of changes was suboptimal for our purpose. For example, dates for each change in outcome were specified, however, how that date related to important events such as initial or final subject recruitment was not transparent (although all relevant dates could be determined and compared with significant effort). In addition, all changes were formatted as fields for data entry (e.g., “<textblock>”) and using abbreviations that were not defined. Such a format is not user-friendly and the meaning was unclear at times. When results were added to the registry, they were listed also on the “History of Changes” page, but without any formatting and with their data entry code: a format of little use to a reader. (The results were clearly presented in the “Study Results” tab, however).

#### Preliminary Recommendations for Changes in ClinicalTrials.gov

From our experience trying to identify and characterize SOR and SAR from information in trial registries, and from using ClinicalTrials.gov in particular, we present a number of suggestions for improving ClinicalTrials.gov and registries in general (Box 2). These suggestions are based solely on this exploratory work, and they need to be further vetted and validated before being implemented. Our suggestions are of two types: the first related to presentation and ease of use of the information contained in the registry; and second to the content of the registry. We will address both types, focusing only on ClinicalTrials.gov in view of its dominance in our study. Our suggestions are confined to the use of a trial registry for obtaining information on potential SOR and SAR, and are not intended to encompass other reasons for using a trial registry.

Box 2 ClinicalTrials.gov: Problems and recommendations for changes

###### Problems encountered using ClinicalTrials.gov

1. Outcomes listed on the summary page were frequently inadequately specified (e.g., “glycemic control”)
2. Only “original” and “current” primary and secondary outcomes are listed, although numerous changes in outcomes can have occurred between those two listings.
3. The “History of Changes” tab was difficult to use: labels were unclear and it was difficult to efficiently identify important changes in the outcomes.
4. Safety outcomes were rarely specified in the summary page, and when they were listed often lack specificity.
5. No information of use to detect SAR is provided, such as the analysis set or variables for adjustment.
6. Results were often not posted in the registry and when they were, they were often less complete than those in the publication.

###### Recommended Changes in ClinicalTrials.gov

1. Changes in format
  a. A visual timeline of important dates would assist the reader in evaluating when registration and changes in outcomes occurred with respect to subject recruitment and data analysis.
  b. The “History of Changes” pages should be formatted to facilitate efficient identification of important protocol changes and data labels should be self-explanatory.
2. Changes in content
  a. Primary and secondary outcomes should be specified in detail: what, how, and when.
  b. Any changes in outcomes, both primary and secondary, should be listed with the date and rationale on the registry summary page.
  c. Information on planned analytic approach (e.g., superiority, non-inferiority), the analysis set (e.g., intention-to-treat, as-treated), and variables planned for adjusted analyses should be provided.

##### Changes in Format of ClinicalTrials.gov

A visual timeline of relevant dates would be useful to users of ClinicalTrials.gov. Currently, numerous dates are presented in narrative form in the introductory page and/or the “History of Changes” page. For many dates there is a logical sequence that should occur if bias in the trial is to be minimized. For example, trial registration should always occur prior to commencement of subject recruitment. The presentation of a timeline of critical points in trial design, implementation, analysis, and publication would allow the user to quickly assess whether the chronology of study design and registration was optimal.

The formatting of the “History of Changes” page needs extensive revision to be of optimal use. The user should be able to review types of changes without having to review categories that are not of interest. For example, if the user is only interested in changes in trial protocol methodology such as a change in the primary outcome or followup interval, the user should not have to review spelling corrections that were entered on the same date as the change in study protocol. The current categories of changes are reasonable; however the approach of organizing by date of change is not. In addition, the field codes should be changed to meaningful labels and headings, or eliminated completely. In addition, all listed changes should represent real changes: situations were encountered where a change was listed, but the text before and after appeared identical.

The “History of Changes” page as currently formatted is not appropriate for reporting results. Results are clearly and efficiently presented in the results section: the “History of Changes” could refer the reader there, with documentation of the date of addition of results to the registry.

##### Changes in Content of ClinicalTrials.gov

Primary and secondary outcomes need to be specified in detail in the registry: what the outcome is, how it will be measured (if appropriate), and when it will be measured. For example the outcome A1c needs to be fully qualified, such as “between-group change in A1c (percent) from baseline to 26 weeks.” Listing of vague outcomes like “glycemic control” should not ever be permitted in trial registries, particularly after subject recruitment has begun. Precise prespecification of outcomes needs to apply to both “original” and “current,” primary and secondary, and benefits and harms outcomes. Zarin and colleagues in 2011^34^ provide a useful framework for describing the levels of specification of outcomes measures. Ideally trial registries would require that outcomes be prespecified at “level 4, Method of Aggregation,” which refers to how the variable was measured, and the specific measure and timepoint (e.g., change in A1c measured as a continuous outcome at 26 weeks followup and reported as mean change).

Descriptions of changes in outcomes, both primary and secondary, should be readily accessible to the user. Ideally, in addition to the “original” and “current” outcomes now displayed on the trial’s main page, a chronology of all changes in outcomes would be clearly presented. The trialist should also be required to indicate the reason for any change in primary or secondary outcomes that were made after subject recruitment commenced. Substantive changes after that point are rarely indicated, and thus when they occur the study authors need to provide a rationale. Population, intervention, and other important subgroups that are part of confirmatory (vs. exploratory) analyses should also be specified in the registry prior to commencing subject recruitment.

For the purposes of identifying SAR, it would be very useful for trial registries to include prespecification of selected information such as the general analytic approach (superiority, noninferiority, equivalence) and the analysis set (e.g., full analysis set and how that was defined). Other information, such as covariates for adjusted analyses would also be useful.

Ideally trial registries would contain the full study protocols, as has been suggested by other researchers.49 These detailed documents, finalized prior to the start of subject recruitment and only modified with specific and explicit justification, document the study design and analytic approaches that can be used to assess SOR and SAR.

Mechanisms for enforcing registration and the completeness and accuracy of data entries may be required to achieve high quality registries that are most useful to patients, researchers, and systematic reviewers, as has been suggested by others.50

## Suggestions for Identifying and Characterizing Selective Outcome Reporting and Selective Analysis Reporting

As a result of this exploratory work, we developed several suggestions for systematic reviewers to use when trying to determine the frequency and effect of SOR and SAR during a systematic review. These suggestions will inform further discussions as guidance is formulated in future. In view of the paucity of evidence on the prevalence and effect of SOR and SAR on effect estimates and conclusions in systematic reviews, our suggestions should also inform future research agendas.

Most importantly, systematic reviewers need to encompass a broad definition of SOR and SAR, including not only the situation where a subset of the original outcomes measured and analyzed in a trial are fully reported based on the magnitude of the treatment effect or the statistical significance of selected outcomes, but also2 the publication of outcomes and analyses that were not prespecified in the publication methods section or in the trial’s registration information. The reporting of this expanded set of outcomes also represents the selective reporting of outcomes or analyses, likely based on the direction, magnitude, or statistical significance of the results.

### Implications for Systematic Reviewers

The systematic review team needs to be strategic and parsimonious in their efforts to identify SOR and SAR. We suggest that the team consider the following steps in their assessment of potential SOR and SAR:

1. Review trial publication(s) for incompletely reported outcomes in the results section (i.e., ORBIT classes A through D). Although these classes may be infrequent and may also represent writing and journal styles and constraints on the number of words in a publication, they are important classes to identify. We do not suggest trying to identify and categorize the other ORBIT classes by examining only the study publication because the discrepancies identified may reflect for the most part poor writing and not necessarily the selective reporting of outcomes based on the nature and direction of the results.
2. The systematic reviewer should not routinely seek information from trial registries for the purpose of identifying SOR or SAR in every study included in a review. This step is potentially very resource intensive and the gain in understanding of SOR and SAR is likely to be minimal. In addition, we were not able to identify predictors of SOR/SAR in our small cohort of studies that had little variation in several of the potential predictors that we examined. Until further research is available to inform such predictors, we offer the following suggestions based on our experience.
  a. If there is a concern about SOR in a trial publication, either because of incomplete reporting of outcomes, missing outcomes that likely should have been reported, or other clues, trial registration should be sought out, and if identified, the registry should be searched for reference to a trial protocol and for results posted to the registry.
  b. If the trial registry does not include results or reference to a study protocol, we do not recommend further exploration of the summary information provided in the registry because the additional information is unlikely to be helpful.
  c. In the absence of specific reference to study registration in the publication, only search registries for RCTs. Nonrandomized studies are not registered frequently enough for searches to be worthwhile.
  d. Given the current focus of registries on outcomes of benefit, at present we suggest searching only for outcomes of benefit, and not harms outcomes unless the latter were likely to have been prespecified as the trial’s primary or secondary outcome. In our experience, useful prespecification of safety outcomes was even less common than for efficacy and effectiveness outcomes.
3. When searching for registered trials, use the World Health Organization ICTRP portal. This search engine accesses a number of different trial registries at once including ClinicalTrials.gov.
4. Comparison of the methods and results sections of trial publications will rarely provide useful information for identifying and characterizing SOR or SAR. The methods section of publications is most likely written after data analyses were completed, and discrepancies between the methods and results sections likely represent poor writing on the part of the trial’s authors and discrepancies cannot be attributed with certitude to SOR or SAR.