# Conclusions

In this exploratory study of a small cohort of RCTs that were included in three CERs, we determined that trials published in or after 2005 and contributing to meta-analyses, were not consistently listed in trial registries. Publications of trials do not consistently report information on trial registration, and reporting of results in ClinicalTrials.gov was inconsistent with no clear reasons for the inconsistencies.

We identified numerous challenges in searching for, and characterizing, SOR and SAR in our cohort of RCTs. We did not find the ORBIT classification tool,3 designed for the assessment of SOR within trial publications, particularly useful. ORBIT has too many categories with too much ambiguity among those categories. ORBIT classes did not describe the types of SOR and SAR that we most frequently encountered: the addition of outcomes measures, subgroups, and other analyses to published results that were not prespecified in the publication methods section or listed in the registry. We consider this type of SOR and SAR as important as the nonreporting of prespecified outcomes.

Trial registries were of little use in identifying SOR unless trial results were listed in the registry, given the current lack of specificity of outcome designation in registries. Registries were of no use in identifying SAR. The presentation and content of ClinicalTrials.gov, the predominant registry for the trials that we examined, could be improved to better assist the systematic reviewer in identifying potential SOR and SAR. Suggestions for improvements in trial registries, and ClinicalTrials.gov in particular, include: (1) a requirement that outcomes be precisely specified; (2) the reasons for any change in primary or secondary outcomes should be provided by the trialist; (3) improved formatting of the History of Changes section; (4) prespecification of the analysis set and general analytic approach be mandated; and (5) efforts to insure that all available results are posted.

Much further research is needed to develop efficient, tailored approaches to identifying and characterizing SOR and SAR in trials starting with an expanded and simplified classification system and changes to trials registries. Without such improvements, the increased time needed by systematic reviewers to try and identify and characterize SOR and SAR are not likely to be worthwhile. Research ultimately needs to guide systematic reviewers in assessing the direction and magnitude of the effects of missing outcomes and analyses on effect estimates and conclusions in systematic reviews.