# Tables and Figures

Table B1 Oral Hypoglycemic Agents: Summary Table

Table B2 Oral Hypoglycemic Agents: Predictors of SOR/SAR

Table B3 Osteoporosis: Summary Table

Table B4 Osteoporosis: Predictors of SOR/SAR

Table B5 Oral Hypoglycemic Agents: Data Abstraction: Study Funder and Conflicts of Interest

Table B6 Oral Hypoglycemic Agents: Data Abstraction, Study Characteristics

Table B7 Oral Hypoglycemic Agents: Data Abstraction, Study Registration Information

Table B8 Oral Hypoglycemic Agents: Data Abstraction: Outcomes

Table B9 Lipid Modifying Agents: Data Abstraction: Study Funder and Conflicts of Interest

Table B10 Lipid Modifying Agents: Data Abstraction: Study Characteristics

Table B11 Lipid Modifying Agents: Data Abstraction: Study Registration

Table B12 Lipid Modifying Agents: Data Abstraction: Outcomes

Table B13 Osteoporosis: Data Abstraction: Study Funder and Conflicts of Interest

Table B14 Osteoporosis: Data Abstraction: Study Characteristics

Table B15 Osteoporosis: Data Abstraction: Study Registration

Table B16 Osteoporosis: Data Abstraction: Outcomes

Figure B1 Oral Hypoglycemic Agents: Timelines of important dates in registered trials [source of date]

Study registry chronologies are indicated by the dates in the second column for each study.