# Trial Registries

The registration of studies, particularly randomized controlled trials (RCTs), is an important tool for identifying all studies related to key question in a comparative effectiveness review (CER). Registries are also a potential tool for assessing SOR and SAR. In the United States, the U.S. Food and Drug Administration (FDA) Modernization Act of 1997 called for the creation of ClinicalTrials.gov and mandated registration of all efficacy drug trials for serious or life-threatening diseases and conditions conducted under FDA Investigational New Drug Application regulations.1 Each record in ClinicalTrials.gov includes summary information on the study protocol, patient recruitment status, and the location of the study site.

The World Health Organization (WHO) initiated a policy in 2006 requiring trial registration of all medical studies that test treatments on patients or healthy volunteers.2 WHO developed the International Clinical Trials Registry Platform (ICTRP), a global initiative that aims to make information about all clinical trials involving humans publicly available (http://www.who.int/ictrp/network/primary/en/index.html).2 The ICTRP operates a Search Portal, which provides access to information about ongoing and completed clinical trials from a number of different trial registries. ICTRP is not a trial registry, but rather provides a single platform for access to trial registration data sets provided by a number of different trial registries, including the following:

- Australian New Zealand Clinical Trials Registry
- Brazilian Clinical Trials Registry (ReBec)
- Chinese Clinical Trial Registry
- Clinical Research Information Service - Republic of Korea
- Clinical Trials Registry - India
- ClinicalTrials.gov
- Cuban Public Registry of Clinical Trials
- German Clinical Trials Register
- International Standard Randomized Controlled Trial Number (ISRCTN) Registry
- Iranian Registry of Clinical Trials
- Japan Primary Registries Network
- Pan African Clinical Trial Registry
- Sri Lanka Clinical Trials Registry
- The Netherlands National Trial Register

For the purposes of registration, the ICTRP defines a clinical trial as any research study that prospectively assigns human participants or groups of humans to one or more health-related interventions in order to evaluate the effects on health outcomes.2

The International Committee of Medical Journal Editors (ICMJE) established a policy effective July, 2005, that requires prospective trial registration as a condition of publication and delineates the criteria for an acceptable registry.3 The ICMJE requirement led to a marked increase in registration in ClinicalTrials.gov in 2005.^4^ ClinicalTrials.gov is the largest registry accepted by the ICMJE,4 however, the ICMJE also accepts registration in any of the primary registries that participate in the WHO platform. ICMJE journals accept "retrospective registration" (registration occurring after subject enrollment started) of trials that began before July 1, 2005. After that date, however, ICMJE considers publication of trials only if registration occurred before the first patient was enrolled (“prospective registration”).5

Trial registration has further evolved to include the results for some RCTs. The FDA Amendments Act of 2007, effective September, 2008, requires that clinical trial results be made publicly available on the internet in a database of both registry and results, although some exceptions are permitted.6

## Appendix A References

1 Food and Drug Administration Modernization Act of 1997. 1997. Pub L No. 105-115.
2 World Health Organization. International Clinical Trials Registry Platform (ICTRP). 2011. www.who.int/ictrp/en/. Accessed on August 9, 2011.
3 DeAngelis CD, Drazen JM, Frizelle FA, et al. Clinical trial registration: a statement from the International Committee of Medical Journal Editors. JAMA. Sep. 15. 2004;292(11):1363-4. [pmid: 15355936].
4 Zarin DA, Ide NC, Tse T, et al. Issues in the registration of clinical trials. JAMA. May. 16. 2007;297(19):2112-20. [pmid: 17507347].
5 International Committee of Medical Journal Editors. 2009. www.icmje.org/faq_clinical.html. Accessed on August, 9, 2011.
6 United States Code. US Public Law 110-85: Food and Drug Administration Amendments Act of 2007. 2008. http://frwebgate.access.gpo.gov/cgi-bin/getdoc.cgi?dbname=110_cong_public_laws&docid=f:publ085.110. Accessed on May 7, 2012.