# Appendixes

Appendix A Trial Registries

Appendix B Tables and Figures