# Abbreviations and Acronyms

A1c: hemoglobin A1c
ARB: analysis reporting bias
AHRQ: Agency for Healthcare Research and Quality
CERs: comparative effectiveness reviews
EPC: Evidence-based Practice Centers
FDA: United States Food and Drug Administration
ICMJE: International Committee of Medical Journal Editors
ICTRP: International Clinical Trials Registry Platform
IQR: interquartile range
NA: not applicable
NR: not reported
OR: odds ratio
ORB: outcome reporting bias
ORBIT: Outcome Reporting Bias in Trials
RCT: randomized controlled trial
SAR: selective outcome reporting
SOR: selective analysis reporting
WHO: World Health Organization