# Subject Matter Experts

## Experts Consulted for Omega-3 Fatty Acids on Preventing and Treating Cancer and Neurological Disorders

Bruce R. Bistrian, M.D., Ph.D.

Harvard Medical School

Chief, Clinical Nutrition

Beth Israel Deaconess Medical Center

Boston, MA

Cindy D. Davis, Ph.D.

Program Director, Nutritional Science Group

National Cancer Institute

Rockville MD

Anouk Geelen, Ph.D.

University of Wageningen

Wageningen, Netherlands

Helen Lavretsky, M.D.

Department of Psychiatry & Biobehavioral Sciences

University of California, Los Angeles

Los Angeles, CA

Jennifer Malin, M.D.

Division of Hematology and Medical Oncology

University of California, Los Angeles

Los Angeles, CA

Gerda Pot, Ph.D.

Human Nutrition Research Unit

Medical Research Council

Cambridge, United Kingdom

Jennifer G. Robinson, M.D., M.P.H.

Professor, Departments of Epidemiology & Medicine

Director, Lipid Research Clinic

Co-Director, Prevention Intervention Center

University of Iowa

Iowa City, IA

Irwin Rosenberg, M.D.

Jean Mayer USDA Human Nutrition Research Center on Aging

Tufts University

Boston, MA

Walter C. Willett, M.D., Dr.P.H.

Fredrick John Stare Professor of Epidemiology and Nutrition

Chair, Department of Nutrition

Harvard School of Public Health

Boston, MA

## Experts Consulted for Risk Factors and Intermediate Markers for Cardiovascular Disease

Maria Luz Fernandez, Ph.D.

Professor, Department of Nutritional Sciences

College of Agriculture and Natural Resources

University of Connecticut

Storrs, CT

William Harris, Ph.D.

Director, Cardiovascular Health Research Center

Sanford Research/University of South Dakota

Sioux Falls, SD

David A. Lathrop, Ph.D., FAHA

Acting Chief, Heart Failure & Arrhythmia Branch

Division of Cardiovascular Science

National Heart, Lung, and Blood Institute

Bethesda, MD

Alice H. Lichtenstein, D.Sc.

Gershoff Professor of Nutrition Science and Policy, Friedman School

Director and Senior Scientist, Cardiovascular Nutrition Laboratory

Jean Mayer USDA Human Nutrition Research Center on Aging

Tufts University

Boston, MA

Michael Miller, M.D., FACC, FAHA

Professor of Medicine, Epidemiology & Public Health

Director, Center for Preventive Cardiology

Division of Cardiology

University of Maryland Medical Center

Baltimore, MD

Walter C. Willett, M.D., Dr.PH.

Fredrick John Stare Professor of Epidemiology and Nutrition

Chair, Department of Nutrition

Harvard School of Public Health

Boston, MA