# References

1 French SD, McDonald S, McKenzie JE, et al. Investing in updating: how do conclusions change when Cochrane systematic reviews are updated?. BMC Med Res Methodol. 2005;5:33. [pmid: 16225692].
2 Shekelle P, Eccles MP, Grimshaw JM, et al. When should clinical guidelines be updated?. BMJ. Jul. 21. 2001;323(7305):155-7. [pmid: 11463690].
3 Shekelle PG, Ortiz E, Rhodes S, et al. Validity of the Agency for Healthcare Research and Quality clinical practice guidelines: how quickly do guidelines become outdated?. JAMA. Sep. 26. 2001;286(12):1461-7. [pmid: 11572738].
4 Shekelle P, Newberry S, Maglione M, et al. Assessment of the Need to Update Comparative Effectiveness Reviews: Report of an Initial Rapid Program Assessment. Prepared by the Southern California Evidence-based Practice Center under Contract No. 290-2007-10062-1. Rockville, MD. Agency for Healthcare Research and Quality. 2009.
5 Shojania KG, Sampson M, Ansari MT, et al. How quickly do systematic reviews go out of date? A survival analysis. Ann Intern Med. Aug. 21. 2007;147(4):224-33. [pmid: 17638714].
6 Shojania KG, Sampson M, Ansari MT, et al. Updating Systematic Reviews. Technical Review No. 16. Prepared by the University of Ottawa Evidence-based Practice Center under Contract No 290-02-0021. Rockville, MD. Agency for Healthcare Research and Quality. September. 2007. AHRQ Publication No. 07-0087.
7 Gartlehner G, West SL, Lohr KN, et al. Assessing the need to update prevention guidelines: a comparison of two methods. Int J Qual Health Care. Oct. 2004;16(5):399-406. [pmid: 15375101].
8 Voisin CE, de la Varre C, Whitener L, et al. Strategies in assessing the need for updating evidence-based guidelines for six clinical topics: an exploration of two search methodologies. Health Info Libr J. Sep. 2008;25(3):198-207. [pmid: 18796080].
9 Maclean CH, Newberry SJ, Mojica WA, et al. Effects of Omega-3 Fatty Acids on Cancer. Evidence Report/Technology Assessment No. 113. Prepared by the Southern California Evidence-based Practice Center under Contract No. 290-02-0003. Rockville MD. Agency for Healthcare Research and Quality. February. 2005. AHRQ Publication No. 05-E010-2.
10 Maclean CH, Issa AM, Newberry SJ, et al. Effects of Omega-3 Fatty Acids on Cognitive Function With Aging, Dementia, and Neurological Diseases. Evidence Report/Technology Assessment No. 114. Prepared by the Southern California Evidence-based Practice Center under Contract No. 290-02-0003. Rockville, MD. Agency for Healthcare Research and Quality. February. 2005. AHRQ Publication No. 05-E011-2.
11 Balk E, Chung M, Lichtenstein A, et al. Effects of Omega-3 Fatty Acids on Cardiovascular Risk Factors and Intermediate Markers of Cardiovascular Disease. Evidence Report/Technology Assessment No. 93. Prepared by the Tufts-New England Medical Center Evidence-based Practice Center under Contract No. 290-02-0022. Rockville, MD. Agency for Healthcare Research and Quality. March. 2004. AHRQ Publication No. 04-E010-2.
12 Balk EM, Horsley TA, Newberry SJ, et al. A collaborative effort to apply the evidence-based review process to the field of nutrition: challenges, benefits, and lessons learned. Am J Clin Nutr. Jun. 2007;85(6):1448-56. [pmid: 17556679].
13 Landis JR, Koch GG. The measurement of observer agreement for categorical data. Biometrics. Mar. 1977;33(1):159-174. [pmid: 843571].
14 de Luis DA, Izaola O, Aller R, et al. A randomized clinical trial with two omega 3 fatty acid enhanced oral supplements in head and neck cancer ambulatory patients. Eur Rev Med Pharmacol Sci. May-Jun. 2008;12(3):177-81. [pmid: 18700689].
15 Jiang ZM, Wilmore DW, Wang XR, et al. Randomized clinical trial of intravenous soybean oil alone versus soybean oil plus fish oil emulsion after gastrointestinal cancer surgery. Br J Surg. Jun. 2010;97(6):804-9. [pmid: 20473991].
16 Lobo DN, Williams RN, Welch NT, et al. Early postoperative jejunostomy feeding with an immune modulating diet in patients undergoing resectional surgery for upper gastrointestinal cancer: a prospective, randomized, controlled, double-blind study. Clin Nutr. Oct. 2006;25(5):716-26. [pmid: 16777271].
17 de Luis DA, Izaola O, Aller R, et al. A randomized clinical trial with oral Immunonutrition (omega3-enhanced formula vs. arginine-enhanced formula) in ambulatory head and neck cancer patients. Ann Nutr Metab. Mar-Apr. 2005;49(2):95-9. [pmid: 15802904].
18 Okamoto Y, Okano K, Izuishi K, et al. Attenuation of the systemic inflammatory response and infectious complications after gastrectomy with preoperative oral arginine and omega-3 fatty acids supplemented immunonutrition. World J Surg. Sep. 2009;33(9):1815-21. [pmid: 19629583].
19 Ryan AM, Reynolds JV, Healy L, et al. Enteral nutrition enriched with eicosapentaenoic acid (EPA) preserves lean body mass following esophageal cancer surgery: results of a double-blinded randomized controlled trial. Ann Surg. Mar. 2009;249(3):355-63. [pmid: 19247018].
20 Sakurai Y, Masui T, Yoshida I, et al. Randomized clinical trial of the effects of perioperative use of immune-enhancing enteral formula on metabolic and immunological status in patients undergoing esophagectomy. World J Surg. Nov. 2007;31(11):2150-7. discussion 8-9. [pmid: 17653789].
21 Liang B, Wang S, Ye YJ, et al. Impact of postoperative omega-3 fatty acid-supplemented parenteral nutrition on clinical outcomes and immunomodulations in colorectal cancer patients. World J Gastroenterol. Apr. 21. 2008;14(15):2434-9. [pmid: 18416476].
22 Read JA, Beale PJ, Volker DH, et al. Nutrition intervention using an eicosapentaenoic acid (EPA)-containing supplement in patients with advanced colorectal cancer. Effects on nutritional and inflammatory status: a phase II trial. Support Care Cancer. Mar. 2007;15(3):301-7. [pmid: 17021855].
23 Bougnoux P, Hajjaji N, Ferrasson MN, et al. Improving outcome of chemotherapy of metastatic breast cancer by docosahexaenoic acid: a phase II trial. Br J Cancer. Dec. 15. 2009;101(12):1978-85. [pmid: 19920822].
24 Balk EM, Lichtenstein AH, Chung M, et al. Effects of omega-3 fatty acids on serum markers of cardiovascular disease risk: a systematic review. Atherosclerosis. Nov. 2006;189(1):19-30. [pmid: 16530201].
25 Balk EM, Lichtenstein AH, Chung M, et al. Effects of omega-3 fatty acids on coronary restenosis, intima-media thickness, and exercise tolerance: a systematic review. Atherosclerosis. Feb. 2006;184(2):237-46. [pmid: 16084516].
26 Oikawa S, Yokoyama M, Origasa H, et al. Suppressive effect of EPA on the incidence of coronary events in hypercholesterolemia with impaired glucose metabolism: Sub-analysis of the Japan EPA Lipid Intervention Study (JELIS). Atherosclerosis. Oct. 2009;206(2):535-9. [pmid: 19447387].
27 Hartweg J, Farmer AJ, Holman RR, et al. Meta-analysis of the effects of n-3 polyunsaturated fatty acids on haematological and thrombogenic factors in type 2 diabetes. Diabetologia. Feb. 2007;50(2):250-8. [pmid: 17119918].
28 Beydoun MA, Kaufman JS, Satia JA, et al. Plasma n-3 fatty acids and the risk of cognitive decline in older adults: the Atherosclerosis Risk in Communities Study. American Journal of Clinical Nutrition. Apr. 2007;85(4):1103-11. [pmid: 17413112].
29 Beydoun MA, Kaufman JS, Sloane PD, et al. n-3 Fatty acids, hypertension and risk of cognitive decline among older adults in the Atherosclerosis Risk in Communities (ARIC) study. Public Health Nutrition. 2008;11(1):17-29. [pmid: 17625029].
30 Dangour AD, Allen E, Elbourne D, et al. Effect of 2-y n-3 long-chain polyunsaturated fatty acid supplementation on cognitive function in older people: a randomized, double-blind, controlled trial. American Journal of Clinical Nutrition. Jun. 2010;91(6):1725-32. [pmid: 20410089].
31 Dullemeijer C, Durga J, Brouwer IA, et al. n 3 fatty acid proportions in plasma and cognitive performance in older adults. American Journal of Clinical Nutrition. Nov. 2007;86(5):1479-85. [pmid: 17991662].
32 Heude B, Ducimetiere P, Berr C, et al. Cognitive decline and fatty acid composition of erythrocyte membranes--The EVA Study. American Journal of Clinical Nutrition. Apr. 2003;77(4):803-8. [pmid: 12663275].
33 Johnson EJ, McDonald K, Caldarella SM, et al. Cognitive findings of an exploratory trial of docosahexaenoic acid and lutein supplementation in older women. Nutritional Neuroscience. 2008;11(2):75-83. [pmid: 18510807].
34 Morris MC, Evans DA, Tangney CC, et al. Fish consumption and cognitive decline with age in a large community study. Archives of Neurology. Dec. 2005;62(12):1849-53. [pmid: 16216930].
35 Samieri C, Feart C, Proust-Lima C, et al. Omega-3 fatty acids and cognitive decline: modulation by ApoEepsilon4 allele and depression. Neurobiol Aging. 2010. Jun. 4.
36 van de Rest O, Geleijnse JM, Kok FJ, et al. Effect of fish oil on cognitive performance in older subjects: a randomized, controlled trial. Neurology. Aug. 5. 2008;71(6):430-8. [pmid: 18678826].
37 van de Rest O, Spiro A III, Krall-Kaye E, et al. Intakes of (n-3) fatty acids and fatty fish are not associated with cognitive performance and 6-year cognitive change in men participating in the Veterans Affairs Normative Aging Study. Journal of Nutrition. 2009;139(12):2329-36. [pmid: 19828689].
38 van Gelder BM, Tijhuis M, Kalmijn S, et al. Fish consumption, n-3 fatty acids, and subsequent 5-y cognitive decline in elderly men: the Zutphen Elderly Study. American Journal of Clinical Nutrition. Apr. 2007;85(4):1142-7. [pmid: 17413117].
39 Whalley LJ, Deary IJ, Starr JM, et al. n-3 Fatty acid erythrocyte membrane content, APOE varepsilon4, and cognitive variation: an observational follow-up study in late adulthood. American Journal of Clinical Nutrition. Feb. 2008;87(2):449-54. [pmid: 18258638].
40 Yurko-Mauro K, McCarthy D, Rom D, et al. Beneficial effects of docosahexaenoic acid on cognition in age-related cognitive decline. Alzheimers Dement. 2010. Apr. 29.
41 Barberger-Gateau P, Raffaitin C, Letenneur L, Berr C, et al. Dietary patterns and risk of dementia: the Three-City cohort study. Neurology. Nov. 13. 2007;69(20):1921-30. [pmid: 17998483].
42 Devore EE, Grodstein F, van Rooij FJA, et al. Dietary intake of fish and omega-3 fatty acids in relation to long-term dementia risk. American Journal of Clinical Nutrition. Jul. 2009;90(1):170-6. [pmid: 19474131].
43 Huang TL, Zandi PP, Tucker KL, et al. Benefits of fatty fish on dementia risk are stronger for those without APOE epsilon4. Neurology. Nov. 8. 2005;65(9):1409-14. [pmid: 16275829].
44 Kroger E, Verreault R, Carmichael PH, et al. Omega-3 fatty acids and risk of dementia: the Canadian Study of Health and Aging. American Journal of Clinical Nutrition. Jul. 2009;90(1):184-92. [pmid: 19474137].
45 Samieri C, Feart C, Letenneur L, et al. Low plasma eicosapentaenoic acid and depressive symptomatology are independent predictors of dementia risk. American Journal of Clinical Nutrition. Sep. 2008;88(3):714-21. [pmid: 18779288].
46 Schaefer EJ, Bongard V, Beiser AS, et al. Plasma phosphatidylcholine docosahexaenoic acid content and risk of dementia and Alzheimer disease: the Framingham Heart Study. Archives of Neurology. Nov. 2006;63(11):1545-50. [pmid: 17101822].
47 Chiu CC, Su KP, Cheng TC, et al. The effects of omega-3 fatty acids monotherapy in Alzheimer's disease and mild cognitive impairment: a preliminary randomized double-blind placebo-controlled study. Progress in Neuro-Psychopharmacology & Biological Psychiatry. 2008;32(6):1538-44. [pmid: 18573585].
48 Freund-Levi Y, Eriksdotter-Jonhagen M, Cederholm T, et al. Omega-3 fatty acid treatment in 174 patients with mild to moderate Alzheimer disease: OmegAD study: a randomized double-blind trial. Archives of Neurology. Oct. 2006;63(10):1402-8. [pmid: 17030655].
49 de Lau LML, Bornebroek M, Witteman JCM, et al. Dietary fatty acids and the risk of Parkinson disease: the Rotterdam study. Neurology. Jun. 28. 2005;64(12):2040-5. [pmid: 15985568].
50 Miyake Y, Sasaki S, Tanaka K, Fukushima, et al. Dietary fat intake and risk of Parkinson's disease: a case-control study in Japan. Journal of the Neurological Sciences. Jan. 15. 2010;288(1-2):117-22. [pmid: 19819467].
51 Weinstock-Guttman B, Baier M, Park Y, et al. Low fat dietary intervention with omega-3 fatty acid supplementation in multiple sclerosis patients. Prostaglandins Leukotrienes & Essential Fatty Acids. 2005;73(5):397-404.
52 Huntington Study Group T-HDI. Randomized controlled trial of ethyl-eicosapentaenoic acid in Huntington disease: the TREND-HD study. Erratum appears in Arch Neurol 2009 Mar;66(3):305. Archives of Neurology. Dec. 2008;65(12):1582-9. [pmid: 19064745].
53 Puri BK, Bydder GM, Manku MS, et al. Reduction in cerebral atrophy associated with ethyl-eicosapentaenoic acid treatment in patients with Huntington's disease. Journal of International Medical Research. 2008;36(5):896-905. [pmid: 18831882].
54 Engeset D, Dyachenko A, Ciampi A, et al. Dietary patterns and risk of cancer of various sites in the Norwegian European Prospective Investigation into Cancer and Nutrition cohort: the Norwegian Women and Cancer study. Eur J Cancer Prev. Feb. 2009;18(1):69-75. [pmid: 19077568].
55 Virtanen JK, Mozaffarian D, Chiuve SE, et al. Fish consumption and risk of major chronic disease in men. American Journal of Clinical Nutrition. Dec. 2008;88(6):1618-25. [pmid: 19064523].
56 Brasky TM, Lampe JW, Potter JD, et al. Specialty supplements and breast cancer risk in the VITamins And Lifestyle (VITAL) Cohort. Cancer Epidemiol Biomarkers Prev. Jul. 2010;19(7):1696-1708. [pmid: 20615886].
57 Thiebaut AC, Chajes V, Gerber M, et al. Dietary intakes of omega-6 and omega-3 polyunsaturated fatty acids and the risk of breast cancer. Int J Cancer. Feb. 15. 2009;124(4):924-31. [pmid: 19035453].
58 Kim J, Lim SY, Shin A, et al. Fatty fish and fish omega-3 fatty acid intakes decrease the breast cancer risk: a case-control study. BMC Cancer. 2009;9:216. [pmid: 19566923].
59 Shannon J, King IB, Lampe JW, et al. Erythrocyte fatty acids and risk of proliferative and nonproliferative fibrocystic disease in women in Shanghai, China. American Journal of Clinical Nutrition. Jan. 2009;89(1):265-76. [pmid: 19056601].
60 Shannon J, King IB, Moshofsky R, et al. Erythrocyte fatty acids and breast cancer risk: a case-control study in Shanghai, China. American Journal of Clinical Nutrition. Apr. 2007;85(4):1090-7. [pmid: 17413110].
61 Engeset D, Alsaker E, Lund E, et al. Fish consumption and breast cancer risk. The European Prospective Investigation into Cancer and Nutrition (EPIC). Int J Cancer. Jul. 1. 2006;119(1):175-82. [pmid: 16470807].
62 Wakai K, Tamakoshi K, Date C, et al. Dietary intakes of fat and fatty acids and risk of breast cancer: a prospective study in Japan. Cancer Sci. Sep. 2005;96(9):590-9. [pmid: 16128744].
63 Folsom AR, Demissie Z. Fish intake, marine omega-3 fatty acids, and mortality in a cohort of postmenopausal women. Am J Epidemiol. Nov. 15. 2004;160(10):1005-10. [pmid: 15522857].
64 Wirfalt E, Vessby B, Mattisson I, et al. No relations between breast cancer risk and fatty acids of erythrocyte membranes in postmenopausal women of the Malmo Diet Cancer cohort (Sweden). Eur J Clin Nutr. May. 2004;58(5):761-70. [pmid: 15116079].
65 Butler LM, Wang R, Koh WP, et al. Marine n-3 and saturated fatty acids in relation to risk of colorectal cancer in Singapore Chinese: a prospective study. Int J Cancer. Feb. 1. 2009;124(3):678-86. [pmid: 18973226].
66 Daniel CR, McCullough ML, Patel RC, et al. Dietary intake of omega-6 and omega-3 fatty acids and risk of colorectal cancer in a prospective cohort of U.S. men and women. Cancer Epidemiol Biomarkers Prev. Feb. 2009;18(2):516-25. [pmid: 19190143].
67 Pot GK, Majsak-Newman G, Geelen A, et al. Fish consumption and markers of colorectal cancer risk: a multicenter randomized controlled trial. American Journal of Clinical Nutrition. Aug. 2009;90(2):354-61. [pmid: 19553301].
68 Hall MN, Chavarro JE, Lee IM, et al. A 22-year prospective study of fish, n-3 fatty acid intake, and colorectal cancer risk in men. Cancer Epidemiol Biomarkers Prev. May. 2008;17(5):1136-43. [pmid: 18483335].
69 Theodoratou E, McNeill G, Cetnarskyj R, et al. Dietary fatty acids and colorectal cancer: a case-control study. Am J Epidemiol. Jul. 15. 2007;166(2):181-95. [pmid: 17493949].
70 Geelen A, Schouten JM, Kamphuis C, et al. Fish consumption, n-3 fatty acids, and colorectal cancer: a meta-analysis of prospective cohort studies. Am J Epidemiol. Nov. 15. 2007;166(10):1116-25. [pmid: 17823383].
71 Hall MN, Campos H, Li H, et al. Blood levels of long-chain polyunsaturated fatty acids, aspirin, and the risk of colorectal cancer. Cancer Epidemiol Biomarkers Prev. Feb. 2007;16(2):314-21. [pmid: 17301265].
72 Norat T, Bingham S, Ferrari P, et al. Meat, fish, and colorectal cancer risk: the European Prospective Investigation into cancer and nutrition. J Natl Cancer Inst. Jun. 15. 2005;97(12):906-16. [pmid: 15956652].
73 Kojima M, Wakai K, Tokudome S, et al. Serum levels of polyunsaturated fatty acids and risk of colorectal cancer: a prospective study. Am J Epidemiol. Mar. 1. 2005;161(5):462-71. [pmid: 15718482].
74 Larsson SC, Rafter J, Holmberg L, et al. Red meat consumption and risk of cancers of the proximal colon, distal colon and rectum: the Swedish Mammography Cohort. Int J Cancer. Feb. 20. 2005;113(5):829-34. [pmid: 15499619].
75 Lin J, Zhang SM, Cook NR, et al. Dietary fat and fatty acids and risk of colorectal cancer in women. Am J Epidemiol. Nov. 15. 2004;160(10):1011-22. [pmid: 15522858].
76 Chang ET, Balter KM, Torrang A, et al. Nutrient intake and risk of non-Hodgkin's lymphoma. Erratum appears in Am J Epidemiol 2007 Apr 1;165(7):848. Am J Epidemiol. Dec. 15. 2006;164(12):1222-32. [pmid: 17005624].
77 Simon JA, Chen YH, Bent S. The relation of alpha-linolenic acid to the risk of prostate cancer: a systematic review and meta-analysis. American Journal of Clinical Nutrition. May. 2009;89(5):1558S-64S. [pmid: 19321563].
78 Chavarro JE, Stampfer MJ, Hall MN, et al. A 22-y prospective study of fish intake in relation to prostate cancer incidence and mortality. American Journal of Clinical Nutrition. Nov. 2008;88(5):1297-1303. [pmid: 18996866].
79 Chavarro JE, Stampfer MJ, Li H, et al. A prospective study of polyunsaturated fatty acid levels in blood and prostate cancer risk. Cancer Epidemiol Biomarkers Prev. Jul. 2007;16(7):1364-70. [pmid: 17585059].
80 Crowe FL, Allen NE, Appleby PN, et al. Fatty acid composition of plasma phospholipids and risk of prostate cancer in a case-control analysis nested within the European Prospective Investigation into Cancer and Nutrition. American Journal of Clinical Nutrition. Nov. 2008;88(5):1353-63. [pmid: 18996872].
81 Crowe FL, Key TJ, Appleby PN, et al. Dietary fat intake and risk of prostate cancer in the European Prospective Investigation into Cancer and Nutrition. American Journal of Clinical Nutrition. May. 2008;87(5):1405-13. [pmid: 18469265].
82 Park SY, Murphy SP, Wilkens LR, et al. Fat and meat intake and prostate cancer risk: the multiethnic cohort study. Int J Cancer. Sep. 15. 2007;121(6):1339-45. [pmid: 17487838].
83 Pham TM, Fujino Y, Kubo T, et al. Fish intake and the risk of fatal prostate cancer: findings from a cohort study in Japan. Public Health Nutr. May. 2009;12(5):609-13. [pmid: 18664313].
84 Hedelin M, Chang ET, Wiklund F, et al. Association of frequent consumption of fatty fish with prostate cancer risk is modified by COX-2 polymorphism. Int J Cancer. Jan. 15. 2007;120(2):398-405. [pmid: 17066444].
85 Koralek DO, Peters U, Andriole G, et al. A prospective study of dietary alpha-linolenic acid and the risk of prostate cancer (United States). Cancer Causes Control. Aug. 2006;17(6):783-91. [pmid: 16783606].
86 Bidoli E, Talamini R, Bosetti C, et al. Macronutrients, fatty acids, cholesterol and prostate cancer risk. Ann Oncol. Jan. 2005;16(1):152-7. [pmid: 15598953].
87 Wilson RT, Wang J, Chinchilli V, et al. Fish, vitamin D, and flavonoids in relation to renal cell cancer among smokers. Am J Epidemiol. Sep. 15. 2009;170(6):717-29. [pmid: 19651663].
88 Wolk A, Larsson SC, Johansson JE, Ekman P. Long-term fatty fish consumption and renal cell carcinoma incidence in women. JAMA. Sep. 20. 2006;296(11):1371-6. [pmid: 16985229].
89 Hughes MCB, Williams GM, Fourtanier A, et al. Food intake, dietary patterns, and actinic keratoses of the skin: a longitudinal study. American Journal of Clinical Nutrition. Apr. 2009;89(4):1246-55. [pmid: 19244366].
90 Aiko S, Yoshizumi Y, Tsuwano S, et al. The effects of immediate enteral feeding with a formula containing high levels of omega-3 fatty acids in patients after surgery for esophageal cancer. JPEN J Parenter Enteral Nutr. May-Jun. 2005;29(3):141-7. [pmid: 15837772].
91 Snyderman CH, Kachman K, Molseed L, et al. Reduced postoperative infections with an immune-enhancing nutritional supplement. Laryngoscope. Jun. 1999;109(6):915-21. [pmid: 10369282].
92 Pan A, Yu D, Demark-Wahnefried WF, et al. Meta-analysis of the effects of flaxseed interventions on blood lipids. Am J Clin Nutr. Aug. 2009;90(2):288-97. [pmid: 19515737].
93 Saito Y, Yokoyama M, Origasa H, et al. Effects of EPA on coronary artery disease in hypercholesterolemic patients with multiple risk factors: sub-analysis of primary prevention cases from the Japan EPA Lipid Intervention Study (JELIS). Atherosclerosis. Sep. 2008;200(1):135-40. [pmid: 18667204].
94 Hjerkinn EM, Seljeflot I, Ellingsen I, et al. Influence of long-term intervention with dietary counseling, long-chain n-3 fatty acid supplements, or both on circulating markers of endothelial activation in men with long-standing hyperlipidemia. Am J Clin Nutr. Mar. 2005;81(3):583-9. [pmid: 15755826].
95 Caslake MJ, Miles EA, Kofler BM, et al. Effect of sex and genotype on cardiovascular biomarker response to fish oils: the FINGEN Study. Am J Clin Nutr. Sep. 2008;88(3):618-29. [pmid: 18779276].
96 Grundt H, Hetland O, Nilsen DW. Changes in tissue factor and activated factor XII following an acute myocardial infarction were uninfluenced by high doses of n-3 polyunsaturated fatty acids. Thromb Haemost. Apr. 2003;89(4):752-9. [pmid: 12669132].
97 Griffin MD, Sanders TA, Davies IG, et al. Effects of altering the ratio of dietary n-6 to n-3 fatty acids on insulin sensitivity, lipoprotein size, and postprandial lipemia in men and postmenopausal women aged 45-70 y: the OPTILIP Study. Am J Clin Nutr. Dec. 2006;84(6):1290-8. [pmid: 17158408].
98 Cazzola R, Russo-Volpe S, Miles EA, et al. Age- and dose-dependent effects of an eicosapentaenoic acid-rich oil on cardiovascular risk factors in healthy male subjects. Atherosclerosis. Jul. 2007;193(1):159-67. [pmid: 16879829].
99 Rallidis LS, Paschos G, Papaioannou ML, et al. The effect of diet enriched with alpha-linolenic acid on soluble cellular adhesion molecules in dyslipidaemic patients. Atherosclerosis. May. 2004;174(1):127-32. [pmid: 15135261].
100 Lovegrove JA, Lovegrove SS, Lesauvage SV, et al. Moderate fish-oil supplementation reverses low-platelet, long-chain n-3 polyunsaturated fatty acid status and reduces plasma triacylglycerol concentrations in British Indo-Asians. Am J Clin Nutr. Jun. 2004;79(6):974-82. [pmid: 15159226].
101 Lee KW, Blann AD, Lip GY. Effects of omega-3 polyunsaturated fatty acids on plasma indices of thrombogenesis and inflammation in patients post-myocardial infarction. Thromb Res. 2006;118(3):305-12. [pmid: 16154181].
102 Rallidis LS, Paschos G, Liakos GK, et al. Dietary alpha-linolenic acid decreases C-reactive protein, serum amyloid A and interleukin-6 in dyslipidaemic patients. Atherosclerosis. Apr. 2003;167(2):237-42. [pmid: 12818406].
103 Hill AM, Buckley JD, Murphy KJ, et al. Combining fish-oil supplements with regular aerobic exercise improves body composition and cardiovascular disease risk factors. Am J Clin Nutr. May. 2007;85(5):1267-74. [pmid: 17490962].
104 Mita T, Watada H, Ogihara T, et al. Eicosapentaenoic acid reduces the progression of carotid intima-media thickness in patients with type 2 diabetes. Atherosclerosis. Mar. 2007;191(1):162-7. [pmid: 16616147].
105 Maki KC, Dicklin MR, Davidson MH, et al. Baseline lipoprotein lipids and low-density lipoprotein cholesterol response to prescription omega-3 acid ethyl ester added to Simvastatin therapy. Am J Cardiol. May. 15. 2010;105(10):1409-12. [pmid: 20451686].
106 Tuttle KR, Shuler LA, Packard DP, et al. Comparison of low-fat versus Mediterranean-style dietary intervention after first myocardial infarction (from The Heart Institute of Spokane Diet Intervention and Evaluation Trial). Am J Cardiol. Jun. 1. 2008;101(11):1523-30. [pmid: 18489927].
107 Lindman AS, Pedersen JI, Hjerkinn EM, et al. The effects of long-term diet and omega-3 fatty acid supplementation on coagulation factor VII and serum phospholipids with special emphasis on the R353Q polymorphism of the FVII gene. Thromb Haemost. Jun. 2004;91(6):1097-1104. [pmid: 15175795].