# Peer Reviewers

Mike Clarke, D.Phil.

UK Cochrane Centre

Oxford, United Kingdom

Simon French, M.D., M.P.H.

Primary Care Research Unit

The University of Melbourne

Carlton, Victoria, Australia

Sally Hopewell, D.Phil.

Senior Research Fellow

Centre for Statistics in Medicine

University of Oxford

Oxford, United Kingdom