# Methods

## Literature Search and Data Abstraction

The literature searches were conducted by the University of Ottawa Evidence-based Practice Center (UO EPC) using the same key terms as used for the original reviews (see Appendix A). The searches were conducted using a modification of the RAND and Ottawa methods. This method employed an abbreviated literature search strategy that focused on five major (pivotal) general-interest medical journals (Annals of Internal Medicine, British Medical Journal, Journal of the American Medical Association, The Lancet, and New England Journal of Medicine; as per the Ottawa method) supplemented with a small number of specialty journals tailored to each topic, as recommended by content experts at RAND.3 In addition, we included journals that had published three or more articles cited in the original reviews (see Appendix A). However, for the review on cognitive function, the combination of generalist and specialty journals (based on the original review) resulted in a very small number of new titles; therefore, the decision was made to augment that search with an additional search conducted without restricting journals. Furthermore, since the previous evidence base for cognitive function was very small and included many population-based studies with short-term followup periods, an additional search was done to identify whether the previous studies had been updated with longer-term followup data. The starting dates for all searches were set at 1 year prior to the ending dates of the original searches to capture any studies not included in the original searches. The literature search results were sent to the relevant EPC for further analyses (cognitive function and cancer to the RAND EPC; cardiovascular risk factors to Tufts EPC).

The title/abstract lists from the literature searches were screened by members of the respective EPC staffs (dually for cancer and cognitive function, singly for cardiovascular risk factors, based on available resources and numbers of abstracts to be screened and articles to be extracted) and the selections were combined. Full-text articles were obtained for all titles that appeared relevant, and the articles were further screened for inclusion. Eligibility criteria were limited. The only factors considered were whether the study being reported was relevant to one of the Key Questions from the original EPC reviews and whether the study design met the same criteria as for the original reviews. In addition, relevant systematic reviews were also included. For the RAND method, we added any articles cited or recommended by the experts (see below) not already identified in the literature searches. Single reviewer abstraction was done for study design, interventions, pertinent study participant characteristics, outcomes, and findings to a separate evidence table for each of the original reviews.

## RAND Method

### Soliciting Expert Opinion

Based on the method used in the RAND report on updating comparative effectiveness reviews, for each of the reviews we collected a list of topic experts from the original reviews, Technical Expert Panel (TEP), peer reviewers of the reports, and other subject matter experts. For the report on cognitive function, several of the original TEP members and reviewers responded that they were no longer actively pursuing research in the field, and some provided us with names of other experts: thus, we contacted those experts as well as several experts suggested by other TEP members and reviewers. Each expert who agreed to participate completed a disclosure of interest form. We aimed to include at least four experts for each review. Appendix B shows the number of experts contacted for each review. For each original review, we created a form that included the original Key Questions and conclusions. The Key Questions were taken verbatim from the original reviews. The review's conclusions were based on information in the Executive Summary, Discussion chapter, or other summaries. To the extent possible, we quoted the conclusions from the original reviews. For each set of conclusions, we asked the experts whether all of the findings were “almost certainly still supported by the evidence” and, if the answer was “no,” to provide us with any new evidence known to them. For the cardiovascular risk factor review we also asked the experts whether selected risk factors should not be included in any future update and to list additional cardiovascular risk factors or intermediate markers of cardiovascular disease that should be included in a future review on omega-3 fatty acids (Appendix D). We further instructed the experts that we did not expect them to conduct a literature search before providing an assessment, rather if they answered “yes” to the question “has there been new evidence that may change this conclusion,” they were to provide the citations to published studies (see informational letters in Appendix D).

### Compilation of Findings of RAND Method

For each review, we constructed a summary table that included the Key Questions, the original conclusions, the findings of the new literature search, and the expert assessments. Based on this information, we arrived at a set of conclusions, which was added to the summary table. Based on the original RAND methodology, we used a four-category scheme to assess the conclusions in terms of the evidence that they might need updating.4 All conclusions about signals for the possible need to update a review were determined by consensus in several rounds of group discussions within the EPCs based on all relevant information available to us. Subject matter experts did not participate in these discussions. In addition, we reevaluated our conclusions after discussions among the EPCs about our methods. The four categories are:

1. Original conclusion is still valid, and this portion of the original review does not need updating.
2. Original conclusion is possibly out of date, and this portion of the original review may need updating.
3. Original conclusion is probably out of date, and this portion of the original review may need updating.
4. Original conclusion is out of date.

In making the decision to classify a review conclusion into one category or another, we used the following factors when making our judgments:

- If we found no new evidence or only confirmatory evidence and all responding experts judged the conclusion as still valid, we classified the conclusion as still valid.
- If we found some new evidence that might change the conclusion, and/or a minority of responding experts (fewer than half) judged the conclusion as having new evidence that might change the conclusion, we classified the conclusion as possibly out of date.
- If we found substantial new evidence that might change the conclusion, and/or a majority of responding experts (half or more) judged the conclusion as having new evidence that might change the conclusion, then we classified the conclusion as probably out of date.
- If we found new evidence that rendered the conclusion out of date or no longer applicable, we classified the conclusion as out of date. Recognizing that our literature searches were limited, we reserved this category only for situations where a limited search would produce prima facie evidence that a conclusion was out of date, such as the withdrawal of a supplement from the market.

## The Ottawa Method

To apply this method, we used the same literature search output as used for the RAND method but not the studies added by the domain experts. As described in the introduction, the method relies on the search for any of three types of “signals” of the need to update: a qualitative signal, a quantitative component, and an “other” signal. The type of signal sought depends on the body of literature: if the response to a Key Question in the original review included a meta-analysis, a quantitative signal can be sought, using an algorithm developed by the UO EPC. If no previous meta-analyses could be conducted, a qualitative or other signal is sought. We used the same within- and between-EPC group consensus approach to determine signals as we did for the RAND method. We determined signals for the RAND and the Ottawa methods during the same discussions about the evidence. We did not have separate, independent meetings for each method.

### Searching for a Quantitative Signal

The original Ottawa method confined the search for a quantitative signal to one of the primary outcomes or any new mortality outcome. For this report, we conducted the quantitative search for each of the main Key Questions for which a meta-analysis result was reported in the original review or associated journal articles (we excluded questions that assessed outcomes in laboratory animals or in vitro models). For each new original study, beginning with the largest, we conducted a fixed effects analysis, pooling the effect size reported in the original meta-analysis and the new result. This process was repeated with each subsequently smaller trial until we found a signal as defined by the Ottawa method (a change in statistical significance or a relative change in effect magnitude of at least 50 percent) or until all new studies were included in the analysis.

### Searching for a Qualitative Signal

Qualitative signals were ascertained by comparing the findings of the original reviews with the findings of new systematic reviews or “pivotal trials.” As defined by the Ottawa method, pivotal trials were published in one of the pivotal journals described above or trials published in nonpivotal journals but with at least three times the number of participants as the previous largest trial. Lacking such trials, all relevant new studies were reviewed.

The comparison took into account the following criteria: findings that invalidate the previous findings, and “major changes in evidence,” such as evidence that a treatment is in/effective for a specific patient subpopulation not previously considered. The following Web site provides further information on the method: www.ohri.ca/UpdatingSystRevs (see Table 1 for further details). Qualitative signals were assigned based on the entire body of new studies that addressed a particular outcome.

The Ottawa method is silent on how to assign a signal when the original review had no trials addressing a specific question and there are new small trials. This is because the original Ottawa method started with published systematic reviews, for which by definition, there already exist randomized controlled trials (RCTs) sufficient to do a review. However, Agency for Healthcare Research and Quality evidence reviews are based on Key Questions, and situations arise where a Key Question has no existing eligible evidence. We took the conservative approach and labeled these situations where there was no evidence in the original review and some evidence in the update search as “no signal” since the Ottawa method did not define this situation a priori. As a sensitivity analysis, we also assigned these situations as A4 (important changes in effectiveness short of “opposing findings”; see Compilation of All Findings section below), reasoning that had the Ottawa method been required to consider this situation, the method would have judged the existence of some new evidence as being a signal for updating.

### Searching for an “Other” Signal

“Other” signals were sought for Key Questions for which there were no prior meta-analyses and no RCTs, such as questions for which only large cohort or case-control studies were identified. The criteria included a major increase in the number of new studies or a new study with at least three times the number of participants as previous studies. These criteria had to be adapted to account for situations such as a large number of new but smaller studies, when the studies in the original review had been large prospective cohort studies and the new studies were largely smaller nested case-control studies. The results of applying the Ottawa method were documented in the last column of the summary tables for each review.

## Compilation of All Findings

The RAND assessments were compared with the Ottawa assessments for each Key Question and each outcome, and a kappa statistic was calculated for each. As a sensitivity analysis, we also calculated an additional kappa, assigning the “no prior evidence” situation as a signal for updating in the Ottawa method. We used the Landis and Koch13 interpretation of values of kappa to determine the level of agreement.

κ | Interpretation
< 0 | Poor agreement
0.0 – 0.20 | Slight agreement
0.21 – 0.40 | Fair agreement
0.41 – 0.60 | Moderate agreement
0.61 – 0.80 | Substantial agreement
0.81 – 1.00 | Almost perfect agreement