# Introduction

The question of how to determine when a systematic review of the evidence needs to be updated is of considerable interest. Changes in the evidence can have significant implications for clinical practice guidelines and for clinical and consumer decisionmaking that depend on valid systematic reviews as their foundation. The rapidity with which new research findings accumulate makes it imperative that the evidence be assessed periodically to determine the need for a full-scale update of systematic reviews.

The science of identifying signals for updating systematic reviews has been developing for the past decade. Prior to 2001, no methods or criteria existed to determine whether evidence-based products remained valid or whether the evidence underlying them had been superseded by newer work.

The Cochrane Collaboration has striven to update its systematic reviews biennially (driven by policy). However, such updates involve a huge investment of time and effort and might not be appropriate for all topics. Thus, in 2005, members of the Collaboration assessed whether 4-year updates might be adequate for some topics by comparing the results and conclusions of 1998 reviews with their 2002 updates. Among 254 updated reviews, only 23 (9 percent) had a change in conclusion, supporting the idea that a priority approach, rather than an automatic time-based approach, should be used to determine the need for an update.1

Since 2001, the Agency for Healthcare Research and Quality (AHRQ) Evidence-based Practice Center (EPC) program has been conducting studies to develop methods to assess the need for updating evidence reviews, as detailed below.

## The RAND Method

In the late 1990s, AHRQ commissioned the Southern California (RAND) Evidence-based Practice Center at the RAND Corporation to determine whether their clinical practice guidelines needed to be updated and how quickly guidelines go out of date. RAND first devised a conceptual model that consisted of six situations that would require a guideline to be updated or withdrawn.2 These situations included changes in (1) the available interventions, (2) the evidence on the benefits and harms of existing interventions, (3) the outcomes that are considered important, (4) the evidence that current practice is optimal, (5) the values placed on outcomes, and (6) the resources available for health care. Their assessment of the need to update the AHRQ guidelines did not take the final two situations into account as the measurement of these situations was considered beyond the scope of the process. The scope of the task also required that, rather than conducting a series of new systematic reviews, RAND would devise a method that could be feasibly applied to a large number of guidelines. Reasoning that any new findings that differed from the previous findings with sufficient magnitude to warrant reconsideration of a guideline would be both published in a major journal and familiar to experts in the field, they used a combination of a literature search focused on predefined major journals and the guidance of experts from relevant disciplines as a more pragmatic way to help identify potentially significant new evidence. Using this approach, they determined that out of 17 guidelines, new evidence and expert judgment indicated that 7 required a major update; 6 required a minor update; 3 were judged as still valid; and no conclusion could be reached for one guideline. Survival analysis indicated that about half the guidelines were outdated in 5.8 years; at 3.6 years, more than 10 percent of the guidelines were outdated.3

In 2008, RAND was given the task to adapt its abbreviated method to assess the need for updating the comparative effectiveness reviews that had been prepared to that point. Briefly, the application of the method included the following steps. For each review, RAND conducted an abbreviated search of key journals using the same search strategy used for the original reviews, abstracted the findings of relevant articles (new systematic reviews, controlled trials, and if needed, large observational studies), and made a qualitative assessment of whether the new evidence corroborated or diverged from the conclusions of the original reviews. RAND also polled the original technical expert panel members, peer reviewers, and if necessary, other subject matter experts for each review for their assessments of whether the original conclusions remained valid. Combining the findings of both of these processes, RAND assessed the need to update each of the original conclusions based on a four-point scale: Out of date and definitely in need of updating; Probably out of date and in need of updating, Possibly out of date and in need of updating; Still valid (Table 1). The methods and the results of this assessment were written up in a final evidence report that was posted on the EPC Web site and are described in further detail in the Methods chapter of this report.4

Table 1 Ottawa signals and RAND indications for the need for an update

Ottawa Method
Ottawa Qualitative Criteria for Signals of Potentially Invalidating Changes in Evidence
A1 | Opposing findings: A pivotal trial or systematic review (or guidelines) including at least one new trial that characterized the treatment in terms opposite to those used earlier.
A2 | Substantial harm: A pivotal trial or systematic review (or guidelines) whose results called into question the use of the treatment based on evidence of harm or that did not proscribe use entirely but did potentially affect clinical decisionmaking.
A3 | A superior new treatment: A pivotal trial or systematic review (or guidelines) whose results identified another treatment as significantly superior to the one evaluated in the original review, based on efficacy or harm.
Criteria for Signals of Major Changes in Evidence
A4 | Important changes in effectiveness short of “opposing findings”
A5 | Clinically important expansion of treatment
A6 | Clinically important caveat
A7 | Opposing findings from discordant meta-analysis or nonpivotal trial
Quantitative Criteria for Signals of Potentially Invalidating Changes in Evidence
B1 | A change in statistical significance (from nonsignificant to significant)
B2 | A change in relative effect size of at least 50 percent

RAND Method Indications for the Need for an Update
1 | Original conclusion is still valid and this portion of the original report does not need updating
2 | Original conclusion is possibly out of date and this portion of the original report may need updating
3 | Original conclusion is probably out of date and this portion of the original report may need updating
4 | Original conclusion is out of date

## The Ottawa Method

Shojania and colleagues at the University of Ottawa devised a method using survival analysis to assess the need to update reviews and tested it among 100 meta-analyses published from 1995 to 2005.^5^ The method did not involve expert judgment, but instead relied on capturing a combination of quantitative and qualitative signals.

Qualitative signals included major changes in the evidence, either a potentially invalidating change in the evidence or simply a major change in the evidence from new meta-analyses or new pivotal trials (defined as trials that had a sample size at least three times that of the largest previous trial or that were published in one of the five predetermined most influential medical journals). Explicit criteria were applied to the language used to describe the original findings and that of descriptions of new findings. Specifically, the following qualitative signals were used to assess a new body of literature or large or pivotal new studies (Table 1).

To establish the existence of a quantitative signal that a review was out of date, they performed updated meta-analyses combining the results of new trials with the pooled results from the original review using a fixed effects model. Note that the Ottawa method does not require recreating the original pooled analysis. Rather, the original pooled results are considered as one point entering into a new fixed effects model. Only the results for primary outcomes were analyzed. The new pooled result had to meet criteria B1 or B2 in Table 1.

Because of the less-than-ideal quality of the published literature (e.g., the paucity of large randomized controlled trials [RCTs]), the researchers also established a category of “Other” signals. The criteria included a major increase in the number of new studies or a new study with at least three times the number of participants as previous studies.6

Among the 100 reviews (which ranged in time since publication approximately 1 to 10 years), 57 percent showed some sign of being out of date. The median length of survival without displaying such a signal was 5.5 years; although 7 percent of the reviews were out of date by the time they were published, only 4 percent were out of date within a year of the end of the search period. Thus, like the RAND study, this study showed the need for frequent, and in some cases almost immediate, updating. The apparent need for more frequent updating was related to topic and to the study heterogeneity found in the original evidence review.

To compare the comprehensiveness and effort required to employ the RAND abbreviated method with that of a typical full-blown literature search, Gartlehner and colleagues created a streamlined version of the RAND method.7 They then implemented both the abbreviated and the “traditional” approaches to assess the need to update the 1996 U.S. Preventive Services Task Force Guide to Clinical Preventive Services. The study found that although the abbreviated RAND method identified fewer eligible studies than the “traditional approach,” Task Force members who were acting as project liaisons rated none of the studies missed by the abbreviated method as important to assessing the need for an update to the guidelines. Thus, they deemed the revised approach to be an efficient and acceptable method for assessing the need to update a guideline.8

## Recent Efforts to Assess the Need for Updating Reviews

In 2010, AHRQ and the National Institutes of Health Office of Dietary Supplements (ODS) commissioned the RAND EPC, the Tufts EPC at Tufts Medical Center, and the University of Ottawa (UO) EPC to conduct a study to compare the RAND and Ottawa methods for identifying signals for the need for updating. The methods were compared using three evidence reviews conducted by these EPCs on the effect of omega-3 fatty acids for preventing and treating cancer,9 preventing and treating cognitive disorders,10 and on risk factors and intermediate markers for cardiovascular disease11 as test cases. This review presents the results of that comparison. To our knowledge, there has been no prior comparison of these two methods. Indeed, we know of no prior comparison of any methods to detect signals for updating. Furthermore, we are unaware of any major organization currently implementing a systematic assessment of reviews for signals for updating, although interest in this topic is high.

The three original evidence reviews were chosen because they were of interest to ODS, one of the sponsors of the project, who want information about the possible need to update these reviews while also contributing to the science of determining signals for updating. The original evidence reviews were published in 2004 and 2005. The collaboration that produced the reviews, together with a summary of the review topics, was described in a previous publication.12 Briefly, the cancer review examined incident cancer and gastrointestinal cancer recurrence after surgery; 25 studies reported data on 22 clinical and intermediate cancer outcomes.9 Three meta-analyses were performed. The neurological disorders review examined dementia or cognitive function decline in the elderly or those with Parkinson's disease, and multiple sclerosis; 12 studies reported data on 5 clinical and intermediate outcomes.10 No meta-analyses were performed. The cardiovascular evidence review examined the effect of omega-3 fatty acids on 24 cardiovascular risk factors and intermediate outcomes.11 Following the structure of that review, for the current analysis, we treat the evaluation of fish oils and alpha-linolenic acid as two separate evidence reviews.