# Executive Summary

The question of how to determine when a systematic review of the evidence needs to be updated is of considerable interest. The rapidity with which new research findings accumulate makes it imperative that the evidence be assessed periodically to determine the need for a full-scale update.

Since 2001, several methods have been devised to assess the need for a systematic review to be updated. Two of these methods were developed by Evidence-based Practice Centers (EPCs).

The Southern California (RAND) EPC at the RAND Corporation developed a method that combines expert opinion with an abbreviated search of the literature published since the original review (the RAND method). An abbreviated search of key journals is conducted using the same search strategy used for the original review. The findings of relevant articles (new systematic reviews, controlled trials, and, if needed, large observational studies) are abstracted; a qualitative assessment is made of whether the new evidence corroborates or diverges from the conclusions of the original review. Simultaneously, the original expert panel members, peer reviewers, and, if necessary, other subject matter experts are polled for their assessments of whether the original conclusions remain valid. Combining the findings of both of these processes, the research team assesses the need to update each of the original conclusions based on a four-point scale: Out of date and definitely in need of updating; Probably out of date and in need of updating; Possibly out of date and in need of updating; Still valid.

The University of Ottawa EPC (UO EPC) developed a method that uses survival analysis and generates a combination of quantitative and qualitative signals for the need to update reviews (the Ottawa method). The method does not involve expert judgment, but instead relies on capturing a combination of quantitative and qualitative signals. Qualitative signals include major changes in the evidence, either a potentially invalidating change in the evidence or simply a major change in the evidence from new meta-analyses or new pivotal trials (defined as trials with a sample size at least three times that of the largest previous trial or that were published in one of the five predetermined most influential medical journals). Explicit criteria are applied to the language used to describe the original findings and that of descriptions of new findings to assess whether the latter constitute significant departures from the former. To establish the existence of a quantitative signal that a review is out of date, an updated meta-analysis is performed combining the results of new trials with the pooled results from the original review using a fixed effects model. Only the results for primary outcomes are analyzed. The new pooled result must meet one of two criteria: a change in statistical significance (from nonsignificant to significant) or a change in effect size of at least 50 percent.

The Agency for Healthcare Research and Quality and the National Institutes of Health Office of Dietary Supplements commissioned the RAND EPC, the Tufts EPC, and the UO EPC to conduct a study to compare the RAND method with the Ottawa method for identifying signals for the need for updating, using three systematic reviews these EPCs had prepared on the effects of omega-3 fatty acids on preventing and treating cancer (RAND), on preventing and treating neurological disorders (RAND), and on risk factors and intermediate markers for cardiovascular disease (Tufts). The cardiovascular disease risk systematic review was divided into two subtopics because the original data were analyzed separately for fish oil and alpha-linolenic acid (ALA). However, we conducted a single literature search and used a single panel of experts for both parts of the cardiovascular review (described below).

## Methods

PubMed searches were conducted by UO EPC research librarians using the same search strategies they used for the original reviews but limiting the journals accessed for the cancer and cardiovascular risk factor searches to five key general medical journals and five of the top specialty journals, beginning 1 year prior to the publication dates of the original reviews. Members of the research teams screened titles and abstracts to identify relevant articles, reviewed full text articles, and then hand abstracted the study characteristics and findings into evidence tables.

For the RAND method, we contacted the original members of the Technical Expert Panels (TEP), peer reviewers, and additional experts recommended by the TEP if needed and asked them to assess whether, in their expert opinion, the conclusions in the original review were out of date or still relevant. If an expert asserted that a particular conclusion was out of date, we asked that s/he provide a recent reference. We combined these assessments with the summaries of the newly identified literature and based on the total picture, ranked each conclusion as to whether it was definitely out of date (and in need of updating), probably out of date, possibly out of date, or still valid.

Using the Ottawa method, for Key Questions for which pooled analyses were conducted in the original reviews, we first sought new meta-analyses addressing the same Key Questions. In the absence of those, we identified new randomized controlled trials (RCTs), preferably published in pivotal journals or enrolling populations as large as or larger than those in the largest trials in the original reviews. Pivotal journals were defined as one of the five top general medical journals (New England Journal of Medicine, Lancet, Journal of the American Medical Association, Annals of Internal Medicine, and the British Medical Journal) based on a ranking by journal impact factor. For each new original study, beginning with the largest, we conducted a fixed-effects analysis, pooling the effect size reported in the original meta-analysis and the new result, and looked for a change in effect size or in statistical significance. The need to update conclusions for Key Questions for which no prior pooled analyses had been conducted was evaluated by examining the body of literature for each Key Question or subquestion to assess whether it satisfied the criteria for any of a series of qualitative “signals” of the need for updating, such as a finding opposite to the earlier finding or a finding of substantial harm.

We then compared the assessments produced by the RAND and Ottawa methods. We combined all the RAND signals indicating definitely, probably, and possibly out of date into one category, and compared the conclusions between the methods within each clinical topic area by calculating a kappa statistic. Finally, the Ottawa method did not consider whether to evaluate particular Key Question, where the original evidence review identified no studies but the update search identified at least one relevant study, as “no signal” or as a “signal to update.” We performed a sensitivity analysis on these Key Questions.

## Results

For the four topics (cancer; neurologic disorders; cardiovascular risk factors, fish oil; and cardiovascular disease, ALA), the range of agreement varied from a kappa of 0.19 (for fish oil and cardiovascular disease markers) to “almost perfect” agreement, with a kappa of 1.0 (for cognitive function). Overall across all 77 conclusions, agreement was classified as “fair.” In our sensitivity analysis, where we modified the Ottawa criteria using the sensible rule that a signal to update was triggered when there were any new data on a Key Question for which there were no data in the original report, agreement was much better: for three of the four conditions agreement between methods was “substantial” or better, and the overall agreement between methods was “substantial” (Tables A–E).

Table A Overall comparison and kappa statistic for cognitive function

| Ottawa Positive | Ottawa Negative | Total
RAND Positive | 3 | 0 | 3
RAND Negative | 0 | 2 | 2
Total | 3 | 2 | 5

Kappa = 1.0

Table B Overall comparison and kappa statistic for cancer

| Ottawa Positive | Ottawa Negative | Total
RAND Positive | 1 (2^*^) | 3 (2^*^) | 4
RAND Negative | 0 | 18 | 18
Total | 1(2^*^) | 21 (20^*^) | 22

Kappa = 0.36 (0.62^*^)

* Sensitivity analysis (see text)

Table C Overall comparison and kappa statistic for cardiovascular disease markers: fish oil

| Ottawa Positive | Ottawa Negative | Total
RAND Positive | 4 | 6 | 10
RAND Negative | 2 | 14 | 16
Total | 6 | 20 | 26

Kappa = 0.30

Table D Overall comparison and kappa statistic for cardiovascular disease markers: ALA

| Ottawa Positive | Ottawa Negative | Total
RAND Positive | 2 (9^*^) | 9 (2^*^) | 11
RAND Negative | 0 | 13 | 13
Total | 2 (9^*^) | 22 (15^*^) | 24

Kappa = 0.19 (+0.83^*^)

* Sensitivity analysis (see text)

Table E Overall comparison and kappa statistic for all evidence reviews

| Ottawa Positive | Ottawa Negative | Total
RAND Positive | 10 (18^*^) | 18 (10^*^) | 28
RAND Negative | 2 | 47 | 49
Total | 12 | 65 | 77

Kappa = 0.36 (0.64^*^)

* Sensitivity analysis (see text)

## Conclusions

In our primary analysis, overall agreement between methods ranged from nonexistent to “almost perfect.” However, we judge our sensitivity analysis, which makes a reasonable modification to the Ottawa method, as being a more useful measure of agreement between the two methods. In our sensitivity analysis, agreement was “substantial” or better in three of the four conditions. Overall agreement between methods was “substantial.” Many of the situations where the methods resulted in disparate recommendations were of the same general form, namely situations where “other” signals were triggered with the Ottawa method (but these signals were not considered as indicating that the review was out of date) whereas in RAND's method, the judgment was that the new evidence was sufficient to conclude that the original review was probably out of date. For example, for the finding related to the risk of developing one particular type of cancer, there were two existing cohorts with many thousands of subjects, neither reporting any association of fish or omega-3 fatty acids with incidence. To this evidence was added a new case control study (with 600 cases, but not meeting the pivotal article criteria) that reported an association. So, to increase the agreement between the two methods, either these kinds of “other” signals could be elevated to the level of a qualitative signal, or we would need to learn, using the RAND method, not to judge this kind of new data as being sufficient to consider the original conclusion as possibly out of date.

Our results support the hypothesis that either method can be used with confidence that it produces results that are about the same as the other method. However, stronger conclusions will await future replications of our study using different systematic reviews. A decision to update a systematic review might also be informed by the application of both methods, with the results compared to provide additional validation or to highlight areas of disagreement. Factors that may influence the choice of method, although not tested explicitly in this project, could be any of the following:

- Level of expert engagement in the research topic (low levels favor Ottawa)
- Quality and variation in study designs found in the new evidence (low levels favor RAND, as Ottawa is designed with high-quality trials in mind)
- Desire for considering absolute levels of prior evidence, rather than only relative levels (high desire favors RAND, which allows more subjective application of updating signals; Ottawa's relative change signals do not take into the account whether there were originally 2 or 50 studies)
- Desire for a transparent, consistent signaling method that maximizes interrater reliability (high desire probably favors Ottawa, since signals have less flexibility).

In the process of conducting the two update signal methods in parallel, we ignored the findings of one method in evaluating the conclusions of the other. In particular, in conducting the qualitative and quantitative Ottawa methods, we did not include the new studies supplied to us by the domain experts. This artificial approach highlighted that there is not an either/or decision to be made as to which update signal method should be applied in the future. It seems logical that a hybrid approach may be most reasonable, using both input from subject matter experts and searching for pivotal trials or meta-analytic evidence of quantitative signals. Additionally, consideration should be given to the utility of other kinds of signals, such as the continuing use and importance of the original systematic review, the continuing use of the interventions assessed in the review, and whether there is an opportunity for updating the review to lead to a change in practice.

Additionally, although it would have been desirable to compare the resources involved in applying each method, we found it impossible to do that because each EPC was conducting the comparison of the RAND method and the Ottawa method for the same evidence reviews, and the same EPC staff were participating in both applications. Qualitatively, we note that the Ottawa approach alone would involve less work than the RAND method if one of the larger RCTs that were assessed triggered a quantitative signal, as occurred with multiple outcomes for fish oil in the cardiovascular report and the addition of a very large (N=18, 645) RCT from Japan.

Conversely, when no quantitative signal is found even after adding all seven new RCTs, as seen in the assessment for the cancer review, the Ottawa method may take more work than the RAND method.

Further consideration should be given regarding what to conclude when a single expert votes that a topic is out of date and how to interpret experts' votes that a topic is outdated if no supporting evidence is provided. The cardiovascular review, in particular, had several instances where this was the case. For example, one of six experts stated that the original review's finding on blood pressure was out of date (fish oil supplementation results in small decreases in systolic and diastolic blood pressure). However, the one new article reporting on blood pressure was a systematic review that had very similar conclusions to the EPC review. Similarly, the new evidence on fasting glucose and fasting insulin provided by the experts (two of whom stated that the review's conclusions were outdated) were consistent with the original review. And one expert said that the conclusions on coronary restenosis are outdated, but provided no supporting evidence. Notably, sticking to the protocol, the Tufts EPC did not press the experts to provide supporting new evidence beyond the original request in the questionnaire. In the future, followup with the experts could be done easily. Analogously, further consideration needs to be given to the situation where a single trial provides a quantitative signal, where experts did not judge this new evidence to be a signal for updating, and the original EPC also judged the new evidence to be inconclusive in changing the original finding. This situation occurred in the fish oil and low-density lipoprotein–high-density lipoprotein outcomes with the addition of the above-mentioned Japanese trial.

We also had some difficulties implementing the RAND method when evaluating outcomes with sparse data. This difficulty was particularly evident for several cardiovascular risk factor outcomes of ALA intake. Specifically, we had difficulty determining whether outcomes with zero to two studies in the original review were outdated when there were one or two new studies with small or non-significant results. We found that we came to different conclusions each time we reviewed the new evidence.

Finally, we cannot compare the predictive validity of the RAND and Ottawa methods as no actual updates of the original reviews have been done. Such a predictive validity analysis will need to wait until reports assessed for signals are actually updated. When several updates have been performed on evidence reviews that have been analyzed for signals, it will be useful to analyze whether the Ottawa and RAND methods, or a combination of the two, accurately predict whether the updated systematic review will come to new conclusions compared to the original reviews. Additionally, two modifications to the Ottawa method are proposed for immediate use:

1. The extension of the qualitative signals criteria to include nontrial data for those Key Questions where the original review included nontrial evidence.
2. The designation of new evidence—in a situation where the original review had no evidence—as a signal for updating.