# Conclusions

In our primary analysis, overall agreement between methods ranged from “nonexistent” to “almost perfect.” However, we judge our sensitivity analysis, which makes a reasonable modification to the Ottawa method, as being a more useful measure of agreement between the two methods. In our sensitivity analysis, agreement was “substantial” or better in three of the four conditions. Overall agreement between methods was “substantial.” Many of the situations where the methods resulted in disparate recommendations were of the same general form, namely situations where “other” signals were triggered with the Ottawa method (but these signals were not considered as indicating that the review was out of date) whereas in RAND's method, the judgment was that the new evidence was sufficient to conclude that original was probably out of date. For example, for the finding related to the risk of developing one particular type of cancer, there were two existing cohorts with many thousands of subjects, neither reporting any association of fish or omega-3 fatty acids with incidence. To this evidence was added a new case control study (with 600 cases, but not meeting the pivotal article criteria) that reported an association. So, to increase the agreement between the two methods, either these kinds of “other” signals could be elevated to the level of a qualitative signal, or we would need to learn, using the RAND method, not to judge this kind of new data as being sufficient to consider the original conclusion as possibly out of date.

Our results support the hypothesis that either method can be used with confidence that it produces results that are about the same as the other method. However, stronger conclusions will await future replications of our study using different systematic reviews. A decision to update a systematic review might also be informed by the application of both methods, with the results compared to provide additional validation or to highlight areas of disagreement. Factors that may influence the choice of method, although not tested explicitly in the project could be any of the following:

- Level of expert engagement in the research topic (low levels favor Ottawa)
- Quality and variation in study designs found in the new evidence (low levels favor RAND, as Ottawa is designed with high-quality trials in mind)
- Desire for considering absolute levels of prior evidence, rather than only relative levels (high desire favors RAND, which allows more subjective application of updating signals; Ottawa's relative change signals do not take into the account whether you originally had 2 or 50 studies).
- Desire for a transparent, consistent signaling method that maximizes interrater reliability (high desire probably favors Ottawa, since signals have less flexibility)

In the process of conducting the two update signal methods in parallel, we ignored the findings of one method in evaluating the conclusions of the other. In particular, in conducting the qualitative and quantitative Ottawa methods, we did not include the new studies supplied to us by the domain experts. This artificial approach highlighted that there is not an either/or decision to be made as to which update signal method should be applied in the future. It seems logical that a hybrid approach may be most reasonable, using both input from subject matter experts and searching for pivotal trials or meta-analytic evidence of quantitative signals. Additionally, consideration should be given to the utility of other kinds of signals, such as the continuing use and importance of the original systematic review, the continuing use of the interventions assessed in the review, and whether there is an opportunity for the updating of the review to lead to a change in practice.

Additionally, although it would have been desirable to compare the resources involved in applying each method, this was not possible because each EPC was conducting the two methods simultaneously and the same Evidence-based Practice Center (EPC) staff were participating in both applications. Qualitatively, we note that the Ottawa approach alone would involve less work than the RAND method if one of the later randomized controlled trials (RCTs) that were assessed triggered a quantitative signal, as occurred with multiple outcomes for fish oil in the cardiovascular report and the additions of a very large (N=18,645) RCT from Japan. Conversely, when no quantitative signal is found even after adding all the seven new RCTs, as was seen in the assessment for the cancer review, the Ottawa method may take more work than the RAND method.

Further consideration should be given regarding what to conclude when a single expert votes that a topic is out of date and how to interpret experts' votes that a topic is outdated if no supporting evidence is provided. The cardiovascular review, in particular, had several instances where this was the case. For example, one of six experts stated that the original review's finding on blood pressure was out of date (fish oil supplementation results in small decreases in systolic and diastolic blood pressure). However, the one new article reporting on blood pressure was a systematic review27 that had very similar conclusions to the EPC review. Similarly, the new evidence on fasting glucose and fasting insulin provided by the experts (two of whom stated that the review's conclusions were outdated) were consistent with the original review. And one expert said that the conclusions on coronary restenosis are outdated, but provided no supporting evidence. Notably, sticking to protocol, the Tufts EPC did not press the experts to provide supporting new evidence beyond the original request in the questionnaire. In the future, followup with the experts could be done easily. Analogously, further consideration needs to be given to the situation where a single trial provides a quantitative signal, where experts did not judge this new evidence to be a signal for updating, and the original EPC also judged the new evidence to be inconclusive in changing the original finding. This situation occurred in the fish oil and low-density lipoprotein–high-density lipoprotein outcomes with the addition of the above mentioned Japanese trial

The Tufts EPC had some difficulties implementing the RAND method when evaluating outcomes with sparse data. This difficulty was particularly evident for several cardiovascular risk factor outcomes of alpha-linolenic acid intake. Specifically, we had difficulty determining whether outcomes with zero to two studies in the original review were outdated when there were one or two new studies with small or nonsignificant results. We found that we came to different conclusions each time we reviewed the new evidence.

Finally, we cannot compare the predictive validity of the RAND and Ottawa methods, as no actual updates of the original reviews have been done. Such a predictive validity analysis will need to wait until reports assessed for signals are actually updated. When several updates have been performed on evidence reviews that have been analyzed for signals, it will be useful to analyze whether the Ottawa and RAND methods, or a combination of the two, accurately predict whether the updated systematic review will come to new conclusions compared to the original reviews. Additionally, two modifications to the Ottawa method are proposed for immediate use:

1. The extension of the qualitative signals criteria to conclude nontrial data for those Key Questions where the original review included non-trial evidence.
2. The designation of new evidence in a situation where the original review had no evidence as an A4 signal for updating.