# Informational Letters

## Cognitive Function

Figure D1 Informational letter for cognitive function

Figure D1 is an informational letter and table that was sent out to the subject matter experts on the topic of Cognitive Function asking for their feedback on the whether the conclusions to the prior report remained up-to-date or whether the report needed updating. The table consists of 4 columns and multiple rows. The first column header states that this column lists the conclusions from the executive summary of the original evidence report. The second column header asks if the conclusion is still supported by the evidence and asks the experts to put a checkmark in a box if the answer is “Yes.” The third column header asks if there has been new evidence that may change the conclusion and asks experts to write in or provide the reference(s) for the new evidence. The fourth column header asks experts to indicate if they do not know whether the conclusion is still up-to-date. Each subsequent row except the last lists the key questions and conclusions in the left-hand column. However the last row asks the experts to provide citations or data of articles that may be of interest.

## Cancer

Figure D2 Informational letter for cancer

Figure D2 is an informational letter and table that was sent out to the subject matter experts on the topic of the Effects of Omega-3 Fatty Acids on Cancer asking for their feedback on the whether the conclusions to the prior report remained up-to-date or whether the report needed updating. The table consists of 4 columns and multiple rows. The first column header states that this column lists the conclusions from the executive summary of the original evidence report. The second column header asks if the conclusion is still supported by the evidence and asks the experts to put a checkmark in a box if the answer is “Yes.” The third column header asks if there has been new evidence that may change the conclusion and asks experts to write in or provide the reference(s) for the new evidence. The fourth column header asks experts to indicate if they do not know whether the conclusion is still up-to-date. Each subsequent row except the last lists the key questions and conclusions in the left-hand column. However the last row asks the experts to provide citations or data of articles that may be of interest.

## Cardiovascular Risk Factors

Figure D3 Informational letter for cardiovascular risk factors

Figure D3 is an informational letter and table that was sent out to the subject matter experts on the topic of Cardiovascular Risk Factors asking for their feedback on the whether the conclusions to the prior report remained up-to-date or whether the report needed updating. The table consists of 4 columns and multiple rows. The first column header states that this column lists the conclusions from the executive summary of the original evidence report. The second column asks if the conclusion is still supported by the evidence and asks the experts to put a checkmark if it is “true,” “not true,” “do not know” or “do not update this outcome.” The third column header asks if there has been new evidence that may change the conclusion and asks experts to write in or provide the reference(s) for the new evidence. The fourth column header asks experts to indicate if they do not know whether the conclusion is still up-to-date. Each subsequent row except the last lists the key questions and conclusions in the left-hand column. However the last row asks the experts to provide citations or data of articles that may be of interest.