# Evidence Tables

## Cognitive Function

Table C1 Effects of omega-3s on cognitive function with aging and on risk for dementia and other neurological disorders

Article ID / Cohort/First Author/Year | Sample(n)/Inclusion Criteria/Exclusion Criteria | Study Design/Intervention or Independent Variable/Duration | Disorder or Condition/ Ascertainment/ Outcome(s) Assessed/ | Findings
Key Question 1 – Cognitive Function
| | | | 2005 Report Conclusion –; - 1 study (n=818, all men), found weak evidence of positive effect; - Fish consumption weakly associated with reduced risk of cognitive impairment; no association with cognitive decline; - Omega-3 FA consumption not associated with cognitive impairment or decline
Atherosclerosis Risk in Communities (ARIC) Beydoun, 2007^28^ | N: 2,251 subjects in Minnesota Inclusion: Age 50+ Exclusion: None specified | Design: Prospective cohort study Intervention: None; primary independent variable was plasma fatty acid concentration of n-3 HUFAs (DHA + EPA) at baseline, reported as two biomarkers – phospholipids fraction and cholesteryl ester Other independent variables: Broad set of nutritional, demographic, and clinical measures Duration: 6 years change in cognition; cognitive testing was done at 3 and 9 years after baseline plasma sampling | Condition: Cognitive function Outcomes: Odds ratio of a composite measure of global cognitive decline across three tests (delayed word recall, digit symbol substitution, and word fluency), called the Reliable Change Index (RCI), set at a threshold value of RCI to indicate decline. | The adjusted OR was not significant for a one SD change in cholesteryl ester or plasma phospholipid fractions for total n-3 PUFAs, EPA, or DHA, and global cognitive decline. Subgroup analysis found that subjects with higher plasma DHA+EPA had a significantly lower OR for decline in verbal fluency in both plasma biomarkers. DHA+EPA were significantly more protective in subjects with hypertension, dyslipidemia, and low depression scores. Conclusion: Plasma fatty acid concentrations of n-3 PUFAs are protective against cognitive decline for some groups. Comparison to 2005 report: Meets criterion A4, important changes in effectiveness. Some evidence of a positive effect, new information about interactions
Atherosclerosis Risk in Communities (ARIC)^a^ Beydoun, 2008^29^ | N: 7,814 subjects in 4 U.S. communities Inclusion: Age 50+ Exclusion: None specified | Design: Prospective cohort study Intervention: None; primary independent variable was n-3 PUFA and HUFA intake as % of total energy intake, measured by Willett dietary FFQ at baseline and at 6 years (n=7,814). Plasma FA data were also reported for a subset of subjects (n=2,251), using the same data from Beydoun 2007 Other independent variables: Broad set of nutritional, demographic, and clinical measures Duration: 6 years change in cognition; cognitive testing was done at 3 and 9 years after baseline plasma sampling | Condition: Cognitive function Outcomes: OR as defined in Beydoun 2007 for global cognitive decline, and additionally for each individual cognitive test | Increased dietary intake of long-chain n-3 FA and balancing n-3:n-6 FA ratio decreased the risk of cognitive decline in verbal fluency, but not the other 2 cognitive tests or for global cognitive function. This finding also held for plasma biomarkers of cholesteryl ester and phospholipid fractions. Significant effects were more pronounced among hypertensive subjects, dietary intake and plasma variables. Conclusion: Dietary intake of n-3 FAs are protective against cognitive decline in verbal fluency for hypertensive subjects. Comparison to 2005 report: Meets criterion A4, important changes in effectiveness, and A6, clinically important caveat. Some evidence of a positive effect, new information about interactions.
Older People And n-3 Long-chain poly-unsaturated fatty acids (OPAL) Dangour, 2010^30^ | N: 867 subjects from 20 general practices in the U.K.; 55% men Inclusion: Healthy, age 70–79 Exclusion: Current diagnosis of dementia or diabetes, recent bereavement, terminal illness, current daily use of fish oil supplements, Mini-Mental State Exam (MMSE) score <24 | Design: Randomized, double-blind, placebo-controlled study Intervention: Dietary supplement of 2 × 650-mg pills, treatment (200 mg EPA and 500 mg DHA) or placebo group (olive oil - n-9 fatty acids). Other independent variables: Sociodemographic and medical factors, frequency and type of fish consumption, GHQ-30 score Duration: 24 months of treatment | Condition: Cognitive function in healthy subjects Outcomes: Mean score on a memory test from the California Verbal Learning Test (CVLT); secondary outcomes were mean scores of other tests of memory (story recall, spatial memory), processing speed, reaction time, and executive function | After 24 months of treatment, there was no difference in primary or secondary cognitive function measures between treatment and control groups. Conclusion: Fish oil supplementation does not affect cognitive function in healthy older people. Comparison to 2005 report: Does not meet criteria for change. Additional evidence strengthens prior conclusions of no effect.
Folic Acid and Carotid Intima-media Thickness (FACIT) trial Dullemeijer, 2007^31^ | N: 404, age 50–70, 71% male subjects from a population study in the Netherlands Inclusion: Subjects were drawn from the placebo arm of a randomized study of folic acid supplementation Exclusion: No notable exclusions (e.g., inadequate blood sample, refusal to participate) | Design: Prospective cohort study Intervention: None; primary independent variable was plasma cholesteryl esters of n-3 PUFAs (sum of EPA + DPA + DHA levels) Other independent variables: Broad range of dietary, demographic, clinical, and genotype variables. Duration: 3 years | Condition: Cognitive function Outcomes: Performance on 5 cognitive tests that measured sensorimotor speed, complex speed, memory, information processing speed, and word fluency | Longitudinal analysis over 3 years found increased concentration of plasma n-3 PUFAs was associated with a small but significantly better performance on sensorimotor speed and complex speed tests, but not significantly associated with the other 3 cognitive tests. Cross-sectional analysis found no significant association. Conclusion: The study provides weak evidence of a small but positive link between plasma n-3 PUFA concentration and cognitive function. Comparison to 2005 report: Does not meet criteria for change. Additional evidence strengthens prior conclusions of weak effect.
Etude du Vieillissement Arteriel (EVA) cohort Heude, 2003^32^ | N: 246, age 63–74, 41% male, from Nantes, France Inclusion: None specified Exclusion: None specified | Design: Prospective cohort study Intervention: None; primary independent variable was plasma erythrocyte n-3 PUFA concentration Other independent variables: Age, sex, education level, initial MMSE score Duration: 4 years | Condition: Cognitive decline Outcomes: Risk of a small cognitive decline of 2+ points on MMSE test; adjusted odds ratio of a moderate (1 SD) difference in cognitive decline | Subjects with small cognitive decline (2+ point MMSE) in 4 years had significantly lower plasma concentrations of total n-3 PUFAs, DHA, EPA, n-3:n-6 ratio, and DHA:AA ratio. The OR for a moderate cognitive decline (1-SD difference) was significantly lower for subjects with higher plasma levels of all of the above, except EPA. Conclusion: The study finds evidence that plasma n-3 PUFA levels are correlated with cognitive decline. Comparison to 2005 report: Meets criterion A4, important changes in effectiveness. Evidence of a positive effect.
Johnson, 2008^33^ | N: 49 women from the general U.S. population, age 60–80 Inclusion: Healthy, non-smoking Exclusion: Taking mineral oil or medications that interfere with fat-soluble vitamin absorption, use of steroids or NSAIDs or antihistamines, recent nutrient or carotenoid supplement use, selected medical conditions | Design: Randomized, controlled study Intervention: Placebo (n=10), DHA (n=14), lutein (n=11), or DHA+lutein (n=14) treatment, all subjects also took BoostPlus nutritional energy drink Other independent variables: FFQ at baseline, 2 months, and 4 months, including DHA and lutein intake Duration: 4 months | Condition: Cognition (and eye health) Outcomes: Mean and SD of score on measures from nine different validated cognitive tests of memory, processing speed, attention, and mood | Only the verbal fluency test delayed recall showed significant improvement in performance for the DHA and DHA+lutein group, as compared to placebo. The MIR apartment test's delayed recall measure also showed significant improvement in the DHA+lutein group only. Conclusion: There is positive, but very weak evidence of a benefit of DHA supplementation on cognitive function. Comparison to 2005 report: Does not meet criteria for change.
Chicago Health and Aging Project Morris, 2005^34^ | N: 3,718 subjects, aged 65+ in a Chicago, IL community Inclusion: None specified Exclusion: Invalid FFQ | Design: Prospective cohort study Intervention: None; primary independent variable was dietary intake of fish (not specific to fatty fish) assessed [underlined: once] by FFQ (median of 1.2 years from baseline evaluation); omega-3 FA levels derived from FFQ report Other independent variables: Broad set of dietary, demographic, cognitive, physical, lifestyle, medical, and psychological variables Duration: 6 years | Condition: Cognitive decline Outcomes: Rate of cognitive decline in a global cognitive score derived from 4 standardized tests | In an expanded adjustment model (but not in a basic model), rate of cognitive decline was significantly slower in subjects that consumed fish one or two times a week, compared to those that consumed fish zero times a week. A model adjusting for various dietary intakes did not find consistent evidence of a trend between quartile of fish intake and rate of change in cognitive score. Conclusion: The study found weak evidence of a positive association between fish consumption and slower cognitive decline. Comparison to 2005 report: Does not meet criteria for change. Additional evidence strengthens prior conclusions of weak effect.
Three-city (3C) study Samieri, 2010^35^ | N: 1,228 community dwellers in Bordeaux, Dijon, and Montpelier, France, aged 65+, mean age 74, 39% male Inclusion: Noninstitutionalized Exclusion: Dementia at baseline, incomplete MMSE at followup | Design: Prospective cohort study Intervention: None; primary independent variable was plasma fatty acid proportions of EPA and DHA Other independent variables: Socio-demographic information, major medical risk factors, medical use, ApoE-e4 allele carrier status Duration: Followup at 2, 4, and 7 years after baseline exam | Condition: Cognitive decline Outcomes: Average annual change in mean and SD of score on MMSE, Isaacs Set Test (IST), Benton Visual Retention Test (BVRT), and Trail-Making Test A and B (TMT-A and –B) | ApoE-e4 carriers had significantly higher average annual decline on MMSE than noncarriers, although the amount of change was small (-0.21 vs. -0.12 for mean scores 27.35 and 27.54). In adjusted models, neither plasma DHA nor plasma EPA proportion were significantly associated with change in any of the four cognitive scores over time. However, ApoE-e4 carrier status increased the predicted mean BVRT score decline over time, with the lowest plasma DHA groups seeing the largest decline. The same conclusion was found for plasma EPA, but high depressive symptoms had an additive effect on cognitive decline for low-EPA groups. Conclusion: Plasma EPA and DHA are associated with cognitive decline over time, and ApoE-e4 carrier status and depressive symptoms (for DHA) strengthen this relationship. Comparison to 2005 report: Meets criterion A4, important change in effectiveness, and criterion A6, clinically important caveat. Evidence of a positive effect, new information about modulation by ApoE-e4 status.
Van de Rest, 2008^36^ | N: 302 , mean age 70, 55% male subjects in the Netherlands Inclusion: Cognitively healthy (MMSE >21), 65+ years old Exclusion: Depression, MMSE score <21, current or recent fish oil supplement use, intake of more than 800 mg EPA-DHA from fish per day, use of antidepressant or dementia medications; use of more than 4 glasses of alcohol per day | Design: Randomized, double-blind, placebo- controlled study Intervention: Fish oil supplement in low and high doses (400 or 1,800 mg EPA-DHA), or placebo (high-oleic sunflower oil) Other independent variables: Medical history, drug use, alcohol consumption, smoking habits, educational, and marital status. Duration: 26 weeks | Condition: Cognitive function Outcomes: Score and changes in z scores of cognitive tests for sensorimotor speed, executive function, memory, and attention | There was no difference in scores on any of the cognitive tests at baseline, 13, and 26 weeks of treatment for the low-dose, high-dose, or placebo groups. Changes in z scores were not significant either. Conclusion: The study found that supplementation with EPA-DHA did not change cognitive function in healthy subjects. Comparison to 2005 report: Does not meet criteria for change. Additional evidence strengthens prior conclusions of no effect.
Veterans Administration Normative Aging Study (NAS) Van de Rest, 2009^37^ | N: 313 male U.S. veterans aged 21–81 (mean age 42) Inclusion: None specified Exclusion: Fish oil or cod liver use | Design: Prospective cohort study Intervention: None; primary independent variable was Willett FFQ including fatty fish intake (tuna and dark-meat fish including bluefish, mackerel, salmon, sardines, swordfish) and n-3 PUFA derived from fatty fish intake. Diet assessed at baseline only. Other independent variables: Education, medical history Duration: 6 years | Condition: Cognitive function Outcomes: 6-year cognitive change in mean and SD scores for cognitive tests including memory, language, speed, and visuospatial ability | Cognitive function did not differ across quartiles of fish or n-3 PUFA intake at 6-year follow-up. Conclusion: Long-term cognitive function is not associated with n-3 PUFA or fatty fish intake. Comparison to 2005 report: Does not meet criteria for change. Additional evidence strengthens prior conclusions of no effect.
Zutphen Elderly Study^b^ Van Gelder, 2007^38^ | N: 210 men, age 70–89, in the Netherlands Inclusion: Healthy subjects Exclusion: Myocardial infarction, stroke, diabetes, cancer at baseline | Design: Prospective cohort study Intervention: None; primary independent variable was the cross-check dietary history assessment at baseline only; analysis was done for total fish consumption and EPA+DHA intake Other independent variables: Demographic, lifestyle, medical information, alcohol/tobacco use, depression scale Duration: 5 years | Condition: Cognitive function Outcomes: 5-year decline in MMSE score | Men who consumed no fish on a daily basis had significant MMSE decline over 5 years, whereas those who consumed 0-20 or >20 g/day did not have significant cognitive decline. Men in the lowest tertile of EPA+DHA intake also had significant decline in cognitive function, whereas the 2^nd^ and 3^rd^ tertiles did not. Conclusion: Low fish consumption and low EPA+DHA intake levels are significantly associated with cognitive decline over 5 years in healthy men. Comparison to 2005 report: Meets criterion A4, important changes in effectiveness. Evidence of positive effect.
Whalley, 2008^39^ | N: 113 subjects in Scotland, aged 63-66 years old Inclusion: Independent living, community dwelling Exclusion: Dementia | Design: Prospective cohort Intervention: None; primary independent variable was plasma fatty acid content of erythrocyte membranes (total n-3 PUFA, DHA, EPA, n-6:n-3 ratio) measured at baseline Other independent variables: APOE genotype Duration: 2 and 4-year | Condition: Cognitive function Outcomes: Cognitive test scores at age 64, 66, and 68 for the: MMSE, Raven's Standard Progressive Matrices (RPM) of non-verbal reasoning, Rey's Auditory Verbal Learning Test (AVLT), Uses of Common Objects, Block Design and Digital Symbol subtests of the Weschler Adult Intelligence scale | Total n-3 PUFA and DHA erythrocyte levels are positively associated with overall cognitive function over time. When adjusted for ApoE-e4 carrier status, the DHA relationship remains significant only for non-carriers. Conclusion: n-3 PUFA and DHA levels are associated with cognitive function over time, but the trend is more consistent for non-carriers of the ApoE-e4 allele. Comparison to 2005 report: Meets criterion A4, important changes in effectiveness, and A6, clinically important caveat. Evidence of a positive effect, new information about ApoE-e4 status
Yurko-Mauro, 2010^40^ | N: 485 subjects aged 55+ years at 19 U.S. sites Inclusion: Subjective memory compliant, met criteria for the DSM IV definition of age-related cognitive decline Exclusion: MMSE score <26, high memory recall scores, use of DHA or omega-3 supplements, medications for Alzheimers Disease, major antipsychotics, or anti-depressants, major medical conditions, alcohol/drug abuse | Design: Randomized, double-blind, placebo-controlled trial Intervention: 900 mg DHA per day vs. placebo (corn/soil oil capsules) Other independent variables: FFQ including DHA and long-chain PUFA intake Duration: 12 and 24-week follow-up | Condition: Cognitive function Outcomes: Primary outcome was change in Cambridge Neuropsychological Test Automated Battery (CANTAB) Paired Associated Learning (PAL) test. Numerous other secondary tests included other CANTAB tests, MMSE, and self-assessed memory. | The DHA group improved significantly on scores for CANTAB PAL, verbal recognition memory (immediate and delayed recall), and Stockings of Cambridge problem-solving after 24 weeks of treatment. No significant change was seen in 4 other cognitive test scores. Conclusion: DHA supplementation improves episodic memory and learning in healthy, older adults with mild memory complaints. Comparison to 2005 report: Meets criterion A4, important changes in effectiveness. Evidence of positive effect.
Key Question 2 – Incidence of dementia/ Alzheimer's disease
| | | | 2005 Report Conclusion –; - 3 studies (n=5,386, 1,122, and 815), consistent evidence of positive effect; - Fish intake associated with reduced risk of Alzheimer's dementia in 1 study, but not significant in other 2 studies; - In 1 study, total omega-3 FA and DHA intake associated with reduced Alzheimer incidence, but not ALA or EPA
Three-City (3C) Study Barberger-Gateau, 2007^41^ | N: 8,085 community dwelling adults in Bordeaux, Dijon, and Montepelier France, age 65+ Inclusion: None specified Exclusion: Dementia at baseline | Design: Prospective cohort study Intervention: No intervention; dietary assessment by FFQ at baseline to ascertain total weekly intake of fish and various fats, including omega-3 rich oils Other independent variables: Sociodemographic information, vascular risk factors, medical history, BMI Duration: 4 years | Condition: Dementia, including AD Outcomes: Incidence and hazard ratio (HR) of dementia (n=281), including AD (n=183) | Regular users of omega-3 rich oils were less likely to develop dementia or AD, and fish intake was also significantly correlated, although the trend was not consistent across increasing fish intake levels. For APOE e4 allele non-carriers, consumption of fish 2–3 times/week reduced the risk of dementia or AD compared to 0–1 times/week, but fish intake 4+ times/week was not significant. The HR for dementia based on regular intake of omega-3 rich oil was lower (p=0.05) in 1 adjustment model, but not in 2 other models; this HR for AD was not significant. Conclusion: The study found some evidence that the incidence of dementia was higher for low fish intake, the incidence of AD was lower for high fish intake, and risk of both conditions was lowers with regular use of omega-3 rich oils. Trends are not consistent with increasing fish intake levels, however. Comparison to 2005 report: No criteria for change met. Some positive effect found, consistent with prior conclusion
Rotterdam Study^c^ Devore, 2009^42^ | N: 5,395 subjects in the Netherlands Inclusion: Free of dementia at baseline Exclusion: Questionable cognitive status, nursing home residence, invalid/incomplete dietary interview responses | Design: Prospective cohort study Intervention: None. Main independent variable was dietary intake at baseline only, using a home-based checklist and dietician-administered FFQ that included total and fatty fish intake; data converted to n3-PUFAs (ALA, DHA, EPA). Other independent variables: Numerous medical/other variables Study was part of a broad population-based study of disease Duration: 10-year average followup | Condition: Dementia and AD Outcomes: Adjusted hazard ratios of incident dementia and AD | Increasing intake of total fish, fatty fish, long-chain omega-3 FA, EPA, and DHA was not associated with a significant HR for developing dementia or AD. Conclusion: The study provides consistent evidence of no association between the incidence of dementia or AD and intake of fish, fatty fish, long-chain omega-3 FA, EPA, or DHA. Comparison to 2005 report: Meets criterion A7, opposing findings from a non-pivotal trial. Conflicts with original findings of a positive effect.
Cardiovascular Health Cognition Study (CHCS)^d^ Huang, 2005^43^ | N: 2,233 subjects in 4 U.S. communities enrolled from Medicare eligibility lists Inclusion: Age 65+ Exclusion: Prevalent dementia or mild cognitive impairment at baseline; invalid FFQ responses | Design: Prospective cohort study Intervention: None; primary independent variable was dietary intake of fish (tuna, fried fish, fish sandwich, or other fish, baked or broiled) assessed once by FFQ at baseline Other independent variables: Age, education, race, gender, BMI, income Duration: Average 5.4 year followup to incidence, max 8.4 year followup | Condition: Dementia and AD Outcomes: Adjusted hazard ratios of incident dementia and AD | Increased consumption of tuna or other fish, but not of fried fish, was associated with a decreased HR of dementia and AD. When stratified by APOE e4 status, noncarriers had a reduced HR of dementia with higher intake of tuna or other fish, although carriers had no significant trends. Conclusion: Intake of some types of fish may reduce risk of developing dementia, but only in APOE e4 noncarriers. Comparison to 2005 report: Meets criterion A6, clinically important caveat. Consistent with positive effect findings, but adds new information about ApoE-e4.
Canadian Study of Health and Aging (CSHA) Kroger, 2009^44^ | N: 663 subjects in Canada, 65+ years old Inclusion: None specified. Exclusion: Dementia at baseline | Design: Prospective cohort study Intervention: None; primary independent variable was plasma erythrocyte membrane level of total n-3 PUFA, DHA, EPA, and mercury Other independent variables: ApoE-e4 carrier status Duration: 4.9-year median follow-up | Condition: Dementia, including AD Outcomes: Adjusted hazard ratios of incident dementia | There was no significant relationship between continuous levels or quartiles of total n-3 PUFA, DHA, EPA plasma levels and incidence of dementia or AD. Adjustment for ApoE-e4 status and mercury levels did not change this result. Conclusion: Plasma n-3 PUFA, DHA, and EPA levels are not associated with incidence of dementia or AD. Comparison to 2005 report: Meets criterion A7, opposing findings from a nonpivotal trial; conflicts with original findings of a positive effect.
Three-City (3C) Study^e^ Samieri, 2008^45^ | N: 1,214 community-dwelling adults in Bordeaux, Dijon, and Montepelier France, age 65+ Inclusion: None specified Exclusion: Dementia at baseline | Design: Prospective cohort study Intervention: None; primary independent variable was plasma FA concentration of total n-3 and n-6 PUFA, ALA, EPA, DHA, and docosapentaenoic acid Other independent variables: ApoE-e4 carrier status, various medical risk factors Duration: 4 years | Condition: Dementia Outcomes: Adjusted hazard ratio of incident dementia | Nonadjusted models found significant relationships between a 1-SD increase in plasma levels of total n-3 PFA, EPA, DHA, and n-6:n-3 PUFA ratio and risk of incident dementia. Adjusted models that included ApoE-e4 status found this relationship significant only for EPA; total n-3 PUFA and DHA were significant in ApoE-e4 adjusted models only when interacted with depressive status. Conclusion: Higher plasma EPA is associated with a lower risk of dementia, as are total n-3 and DHA levels in depressed subjects. Comparison to 2005 report: Meets criterion A6, clinically important caveat. Consistent with positive effect findings, but adds new information about ApoE-e4.
Framingham Heart Study Schaefer, 2006^46^ | N: 899 subjects, 37% male, mean age 76 years Inclusion: Free of dementia at baseline Exclusion: | Design: Prospective cohort study Intervention: None; primary independent variable was plasma PC DHA level as % of total FA, at baseline Other independent variables: FFQ was also administered to quantify DHA and fish intake; broad range of medical, demographic, BMI, and other variables Duration: 9.1-year mean follow-up to development of dementia/AD | Condition: Dementia Outcomes: Relative risk (RR) of all-cause dementia | Higher levels of plasma PC DHA were associated with a significantly lower RR of dementia but not AD, for those in the top quartile of plasma PC DHA levels compared to the 1^st^–3^rd^ quartiles. Significance did not rely upon APOE e4 carrier status, adding this variable into the model did not change findings. Mean DHA and fish intake were significantly correlated with plasma PC DHA, based on FFQ report. Conclusion: High plasma PC DHA levels are associated with reduced RR of developing dementia but not AD, independent of APOE e4 status. Comparison to 2005 report: No criteria for change met; consistent with positive effect findings.
Key Question 3 – Treatment of dementia/ Alzheimer's disease (AD)
| | | | 2005 Report Conclusion –; - 1 study (n=20), some evidence of positive effect; - DHA resulted in a small improvement in scores on the MMSE and Hasegawa dementia rating scale
Chiu, 2008^47^ | N: 35 subjects in Taiwan, aged 55–90 Inclusion: Mild or moderate AD or amnesiac mild cognitive impairment Exclusion: Inadequate motor or sensory skills to complete testing, depression, mental or substance use disorder, other severe comorbidities, NSAID use. Supplements including fish oil discontinued during study, but subjects with prior fish oil use were not reported. | Design: Randomized, double-blind, placebo-controlled study Intervention: n-3 PUFA capsules (1,080 mg EPA and 720 mg DHA daily) or placebo (olive oil) Other independent variables: Depression Duration: 24 weeks | Condition: AD and mild cognitive impairment Outcomes: Age, group-by-time, and unadjusted mean scores of the MMSE, Clinician's Interview-Based Impression of Change (CIBIC-plus), Alzheimer's Disease Assessment Scale (ADAS-cog), and Hamilton Depression Scale (HDRS) | n-3 PUFA supplementation may improve global cognitive function as measured by the CIBC-plus, relative to placebo, for younger subjects. No associations were found between treatment and placebo groups for the ADAS-cog, MMSE, or HDRS scores. Conclusion: There is limited evidence of a positive effect of n-3 PUFA supplementation on cognitive function. Comparison to 2005 report: No criteria for change met; consistent with small positive effect findings.
Freund-Levi, 2006^48^ | N: 174, mean age 74 (SD 9 years) subjects from specialist memory clinics in Stockholm, Sweden Inclusion: AD according to DSM-IV criteria; MMSE score 15–30; living in own home; treatment with stable dose of acetylcholine esterase inhibitors for at least 3 months before start of study and plan to continue treatment for duration of study Exclusion: NSAID use (low-dose acetylsalicylic acid acceptable); use of omega-3 preparations or anticoagulant agents; alcohol abuse; concomitant serious disease; no caregiver. | Design: Randomized, double-blind, placebo-controlled study Intervention: 4 × 1 g capsules daily for treatment and placebo groups with 4 mg vitamin E in each; active pills had 430 mg DHA and 150 EPA, placebo pills had an isocaloric oil (1 g corn oil, including 0.6 g linoleic acid). Treatment for 6 months, followed by 6 months open treatment with omega-3 fatty acid supplementation in all patients Other independent variables: Blood and urine analysis, blood pressure assessments Duration: 6 months treatment or placebo, followed by 6 months treatment both groups | Condition: Mild to moderate Alzheimer Disease Outcomes: Mean scores on MMSE and cognitive portion of the Alzheimer Disease Assessment Scale (ADAS-COG); global function in Clinical Dementia Rating Scale; safety and tolerability of omega-3 fatty acid supplementation also measured | No significant difference at 6 months between treatment and placebo groups, or at 12 months with both groups receiving treatment, for overall MMSE or ADAS-COG scores. A few specific MMSE items showed positive effects of omega-3 FA treatment, but findings may be spurious. Conclusion: Dietary supplementation with omega-3 fatty acids does not appear to improve cognitive function in patients with mild to moderate AD. This is the only randomized, double-blind, placebo-controlled study of omega-3s for treatment of AD known to study authors. Comparison to 2005 report: Meets criterion A7, opposing findings from a non-pivotal trial; negative trend from prior conclusion
Key Question 4 – Incidence of neurological disease (multiple sclerosis, Parkinsons disease, cerebral palsy; excludes dementia)
| | | | 2005 Report Conclusion –; - 4 studies (n=135,384; 399; 224; and 195), no effect or weak evidence of positive effect; - 2 studies found no significant effects of omega-3 FA intake on MS incidence, but 1 study found increased fish intake associated with lower MS risk in women; - 1 study found no significant association between fish consumption, ALA, EPA, or DHA, and risk for Parkinson's disease; - 1 study found weekly maternal fish intake decreased risk of giving birth to a child with cerebral palsy
Rotterdam Study^f^ De Lau, 2005^49^ | N: 5,289 subjects from a population cohort in Rotterdam, the Netherlands, of which 51 were in the disease cohort; ages 55+ Inclusion: Independent living, normal cognition Exclusion: Inconsistent reported food frequency questionnaire intake, dementia, parkinsonism at baseline, dementia | Design: Prospective cohort study Intervention: None. Main independent variable was dietary intake at baseline only, using a home-based checklist and dietician-administered FFQ; data converted to n3-PUFAs (ALA, DHA, EPA) Other independent variables: Numerous medical/other variables Study was part of a broad population-based study of disease Duration: Baseline, 2- and 6-year followup intervals | Condition: Incident PD Outcomes: Hazard Ratio (HR) of PD in the 51 subjects that developed PD in 6 years | Increased n-3 PUFA intake was associated with a lower HR of PD. For specific n-3 PUFA subtypes, ALA was significant (HR 0.65, 95% CI 0.45-0.95), but DHA and EPA were not. The HR was significant for the overall cohort that developed incident PD during the study's 6-year followup (n=51), but not significant at the specific short and long-term followup intervals (2 and 6 years, n=25 and n=26). Conclusion: Higher intake of total n-3 PUFA and ALA may be associated with a lower incidence of PD, although total unsaturated fats are more important. Comparison to 2005 report: Meets criterion A7, opposing findings from a non-pivotal trial. Evidence of a positive effect on incidence of PD; no effect was found in 2005 report.
Miyake, 2010^50^ | N: 617 subjects in Japan (249 cases, 368 controls), mean age 68, 37% male Inclusion: Cases were patients within 6 years of onset of PD, controls were inpatients and outpatients without a neurodegenerative disease, but not matched to cases. Exclusion: None specified | Design: Case-control study Intervention: No intervention; primary independent variable was a validated, self-administered diet history questionnaire Other independent variables: Sex, age, region of residence, education, smoking history, BMI, intake of vitamin E, iron, and alcohol Duration: N/A | Condition: Incidence of Parkinson's disease (PD) Outcomes: Crude and adjusted odds ratio of PD | The OR for PD was not significant based on intake of total n-3 PUFAs, ALA, EPA, DHA, or n:3:n-6 PUFA ratio. Conclusion: The study finds no evidence of an association between n-3 PUFAs and PD incidence. Comparison to 2005 report: No criteria for change met. Consistent with no effect findings.
Key Question 5 – Treatment of multiple sclerosis progression
| | | | 2005 Report Conclusion –; - 3 studies (n=312, 12, and 16), some/inconsistent evidence of positive effect; - 2 studies found a significant reduction in MS disability, one of these reported improvement in disease progression; - 1 study found omega-3 FA supplement had no effect on disability or relapse rates
Weinstock-Guttman, 2005^51^ | N: 27 subjects, age 18–60 Inclusion: Diagnosis of MS, stable disease in past 2 months, 1 or more exacerbations in past 3 years, continued use of normal medications, diet of more than 30% of total calories from fat Exclusion: None specified | Design: Randomized, double-blind, placebo-controlled study Intervention: Low-fat diet for all subjects, 6g fish oil (1.98g EPA, 1.32g DHA) per day treatment group and no more than 15% of total daily calories from fat, vs. 6g olive oil per day for placebo group and no more than 30% of total daily calories from fat Other independent variables: Serum fatty acid concentration of EPA, DHA, and total n-3 PUFAs Duration: 1 year | Condition: MS Outcomes: Quality of life measures – scores on the Primary Component Scale (PCS) and global score of the Short-Form Health Survey (SF-36), Modified Fatigue Impact Scale (MFIS), Mental Health Inventory (MHI); also, immunological parameters. | PCS and MHI improved significantly in the fish oil vs. placebo group at 6 months, but the significant effect disappeared at 12 months; MFIS improved significantly for the placebo group at 6 and 12 months. The global SF-36 score did not change in the fish oil group, and it worsened in the olive oil group, but significance levels were not reported for this outcome. Immunological parameters did not differ significantly between groups at 1 year. Conclusion: Weak evidence of an effect of fish oil supplementation on MS outcomes, but this may also be due to a lower-fat dietary intervention. Comparison to 2005 report: No criteria for change met. Consistent with findings of a weak, possibly positive effect.
Other – Treatment of Huntington Disease
| | | | 2005 Report Conclusion –N/A
Trial of Ethyl-Eicosapentaenoic Acid in Huntington Disease (TREND-HD) Huntington Study Group - TREND-HD Principal Investigators, 2008^52^ | N: 316 (158 in each treatment and placebo groups, 192 completed the study), mean age 53 (SD 10 years), 51% female in Canada and the U.S. Inclusion: Clinical features of HD and either family history or CAG repeat length expansion to confirm HD, 35+ years old, good functional capacity, minimal dystonia, minimal bradykinesia, adequate birth control, ability to take medications orally. Exclusion: Taking exclusionary medications, relevant history of medical/psychiatric/surgical conditions, advanced disease | Design: Randomized, double-blind, placebo-controlled study Intervention: Treatment with ethyl-EPA, 1 g, twice a day vs. placebo (paraffin oil) for 6 months, followed by 6 months treatment for both groups Other independent variables: N/A Duration: 1 year | Condition: HD Outcomes: Primary tests of Total Motor Score 4 (TMS-4) of the Unified HD Rating Scale; numerous other secondary tests of motor skills, cognition, behavior, and function | No difference between treatment and placebo groups on TMS-4, or any secondary tests, in 6 months. At 12 months, those initially randomized to treatment had significantly better TMS-4, chorea score, and total motor score than those initially randomized to placebo; other secondary tests were not significant for differences between groups. Note: Results were publicized after 6 months, leading to drop-out and potential attrition bias – 61% completed the study. Conclusion: Ethyl-EPA was not beneficial for patients with HD during 6 months of placebo-controlled evaluation. Comparison to 2005 report: N/A
Puri, 2008^53^ | N: 34 subjects, age 30–70 years Inclusion: Symptomatic, genetically confirmed HD or family history of HD at stage I or II; scoring between 50 and 90 for Independence Scale component of Unified HD Rating Scale Exclusion: Use of depot antipsychotic medication | Design: Randomized, double-blind, placebo-controlled study Intervention: 2g/day of ethyl-EPA or placebo (liquid paraffin) Other independent variables: Age Duration: 1 year | Condition: HD Outcomes: Mean change in percentage global brain volume, measured by high-resolution cerebral MRI scans; and Voxel-wise analysis of edge displacement | Global brain volume change and edge displacement by Voxel analysis were significantly better in the treatment than placebo group after the 1^st^ 6 months, but not in the 2^nd^ 6 months or over 1 year. Conclusion: Ethyl-EPA supplementation may offer some benefit for patients with HD. No other drug tested in HD has shown this effect. Comparison to 2005 report: N/A

a Same study group as Beydoun 2007, different independent variables (dietary intake in addition to plasma FA), more detailed outcome measure specification also.

b This is the same study population as the one study included in the 2005 report (Kalmijn 1997). Van Gelder et al. concluded that “results of the current study differ from [Kalmijn 1997] … in which no clear inverse association between fish consumption and 3-y cognitive decline could be shown. In the current study, we observed a strong inverse association between EPA+DHA intake and cognitive decline. Possible explanations for the discrepancy … could be the longer follow-up period in the current study and the availability of data on the EPA and DHA content of animal and plant foods in addition to fish and seafood.”

c This is the same study population as one of the studies included in the 2005 report (Kalmijn 1997). The updated study has a longer followup (10 years vs. 2 years), and it conflicts with the earlier study's finding that increased fish intake reduces the risk of dementia.

d Similar/overlapping study group as that used by Beydoun (Key Question 1).

e Same study cohort as Barberger-Gateau (same Key Question), different independent variable and inclusion criteria.

f Same study group used by Devore (Key Question 2).

## Cancer Risk and Response to Treatment

Table C2 Effects of omega-3s on cancer risk and response to treatment

Cohort^*^ or Trial/First Author/Year | Sample^#^(n)/Inclusion Criteria/Exclusion Criteria | Study Design/Intervention or Independent Variable/Duration | Type of Cancer/ Ascertainment/Outcome(s) Assessed | Findings
Key Question 1 Effect on tumor incidence Key Question 1A: What is the evidence that omega-3 fatty acids reduce the incidence of tumors (in humans)? For what type of tumors?
All Cancers: Original report found that “omega-3 fatty acids do not appear to decrease overall cancer risk” based on finding of no effect for most types of cancer
Norwegian European Prospective Investigation into Cancer and Nutrition (NEPIC) Engeset, 2009^54^ | Part of a larger study (NOWAC) which in turn is part of the larger EPIC 37,212 women enrolled in the NEPIC study Exclusion: possible under- or over-reporting of intake; answering fewer than half the FFQ questions, eating >60 hot meals/month, prevalence of cancer (34,471 remained) Women followed until 1^st^ cancer diagnosis, death emigration, or end of followup period | Prospective Cohort 8-page FFQ/lifestyle questionnaire. Fish intake was considered only for colorectal cancer? | Ascertainment by Cancer Registry of Norway of total cancers, breast cancer, colorectal cancer | Women were characterized according to one of 6 dietary patterns based on FFQ (Fish was one pattern) No overall relationship between cancers and the six different dietary patterns in this study Low intakes of fatty fish were associated with higher risks of cancer only in the context of the Western diet (breast cancer) or high intakes of alcohol (total cancers)
Health Professionals Follow-up Study, US Virtanen, 2008^55^ | 40,230 US male health professionals 40-75 y at baseline Exclusion: baseline prevalent MI, angina, other heart disease, stroke, or cancer; ≥70 items missing from food frequency questionnaire; reported energy intake <800 or >4200 cal/d | Prospective Cohort Self-administered semi-quantitative validated food frequency questionnaire (FFQ) at baseline and every 4 years asked about intakes of canned tuna (3–4oz serving), dark-meat fish (e.g., mackerel, salmon, sardines, bluefish, swordfish; 3–5 oz/serving); other fish; and shrimp, lobster, or scallops (3.5 oz, but not included in estimates) to estimate EPA and DHA intakes. Fish oil assessed biennially | All cancers except nonmelanoma skin cancer and low-grade organ-confined prostate cancer Self report triggered blinded medical record review; deaths ascertained from relatives, post office, National Death Index; cause of death ascertained from autopsy records, death certificate | Over 18 yrs followup, 4,690 cancer events No significant associations were seen between fish consumption or EPA+DHA consumption and incidence of total cancer, even when comparing the highest with the lowest decile of intake
Aerodigestive Tract Cancer: Original report identified 1 study (8006 Japanese-American men) that showed no significant effect of fish on the incidence of aerodigestive cancer (Honolulu Heart Program [Chyou 1995]) No new studies identified
Bladder Cancer: Original report identified 1 study (8006 Japanese-American men) that showed no significant effect of fish on the incidence of bladder cancer (Honolulu Heart Program [Chyou 1995]) No new studies identified
Breast Cancer: Original report identified 7 studies (6 cohorts) Fish consumption (4 studies): 1 study found increased risk in highest vs. lowest quartile of fish intake (n=29,875 Caucasian women); other three studies found no effect (n=120,000; 14,729; 121,700) Total and marine n-3 FA (1 study): Highest quartile of marine n-3s had lower risk than women in lowest quartile (n=63,257 Asian women) Specific n-3s (1 study): Highest quartile of ALA had lower risk than lowest quartile (n=62,573 men and women[# women unknown]) No evidence for fish oil, total omega-3s, DHA, or EPA
VITAL Cohort Brasky, 2010^56^ | 35,016 postmenopausal female (50-76 yrs) members of the VITAL cohort, residents of western Washington state Inclusion: response to baseline survey mailed to residents (names purchased from commercial list) Exclusion: Hx of breast cancer at baseline or failure to report on hx; premenopausal or unknown menopausal status. Subsequently women dx w/ in situ breast disease, sarcoma, phyllodes, or lymphoma histology were excluded | Baseline questionnaire on supplement use (herbal and specialty, including mixtures such as multivitamins) in 10 years prior to baseline. Current and past regular use (defined as ≥1day/wk for ≥1 year. Frequency and duration of use measured. (not sure how they explained a supplement or whether they provided a closed-end set from which to choose). Also collected info on other risk factors for BC and correlates of supplement use, ht, wt, physical activity, use of various medications (e.g., NSAIDS), diet (120-item FFQ), Fx hx history of cancer, medical hx, reproductive hx, other lifestyle characteristics | Mean followup time was 6 yrs. Cases ascertained by linking cohort to the regional SEER cancer registry as well as follow-up with area hospitals, pathologists, oncologists, and radiotherapists, and state death certificates | 880 eligible cases of invasive BC dx from 1/00 to 12/07. Current use of fish oil was associated with reduced risk of BC (HR, 0.68, 95% CI, 0.50-0.92). 10-yr average use was suggestive of reduced risk (P trend = 0.09). Results held for ductal but not lobular cancers. No other supplement was associated with BC risk. When the interaction of fish oil with other characteristics thought to influence inflammation was examined, current use of fish oil actually increased the risk for BC in those with hx of CAD but decreased BC risk in those w/ no hx of CAD A previous publication reported on validation and reliability of survey for supplement use assessment Conclusion: effect of fish oil inconsistent: decreased risk of DCIS but not LC. Increased risk in those with history of CAD
E3N (maybe substudy of EPICS) Thiebaut, 2009^57^ | 56,007 French women recruited through their teachers' health insurance program Exclusion: participants in the top and bottom 1% of the ratio of reported energy intake to basal metabolic rate; cancer diagnosis (except basal cell skin carcinoma and lobular breast carcinoma in situ); unavailable followup information; use of vitamin E, C or b-carotene supplements in 1995, 2000 or 2002, (leaving 56,007 subjects). | Dietary questionnaire 8 years of followup | Ascertainment by fx report, postal service, and by searching the health insurance company (MGEN) database. Information on cause of death was obtained from the National Service on Causes of Deaths (INSERM CepiDC). | 1,650 women developed invasive breast cancer. Breast cancer risk was not related to any dietary PUFA overall; Breast cancer risk was inversely associated with α linolenic acid (ALA) intake from fruit and vegetables [highest vs. lowest quintile, hazard ratio (HR) 0.74; 95% confidence interval (CI) 0.63, 0.88; p trend < 0.0001], and from vegetable oils (HR 0.83; 95% CI 0.71, 0.97; p trend 0.017). Conversely, breast cancer risk was positively related to ALA intake from nut mixes (p trend 0.004) and processed foods (p trend 0.068), as was total ALA intake among women in the highest quintile of dietary vitamin E (p trend 0.036). A significant interaction was also found between n-6 and long-chain n-3 PUFAs, with breast cancer risk inversely related to long-chain n-3 PUFAs in women belonging to the highest quintile of n-6 PUFAs (p interaction 0.042). Conclusion: Effects of ALA inconsistent, depending on food source
National Cancer Center Hospital, Korea Kim, 2009^58^ | 979 (362 cases, mean age 48.3; 617 controls, mean age 47.9) women/ Inclusion: Dx breast cancer (BC) Exclusion: prior history of cancer; inability to be interviewed; implausible daily energy intake Matched on age±5 years | Case control FFQ: 8 fish items used to estimate quartiles of intake of lean fatty, total fish, DHA, EPA | Breast cancer diagnosed at cancer center Adjusted odds rations (age, multivariates) for quartiles of intake in pre- and post-menopause | Intakes of fatty fish were associated with a decreased risk of BC in pre- and postmenopausal women (highest vs. lowest quartiles of intake BC risk decreased in postmenopausal women who consumed >0.101g/d EPA and 0.213g/d DHA from fish compared to the reference group (<0.014g/d EPA, 0.037g/d DHA) BC risk decreased in premenopausal women for highest vs. lowest quartile of intake of total n-3 FA Conclusions: results suggest high consumption of fatty fish ∝ reduced BC risk and that n-3 FA intake 1/∝ BC risk
Shanghai Textile Industry Bureau cohort Shannon, 2009^59^ | Women born between 1925 and 1958, permanent residents of Shanghai from breast self-exam trial; 622 women developed fibrocystic changes and 432 developed breast cancer (336 completed FFQ) | Case control Questionnaire completed between 1989 and 1991. Monitored through 2000 for breast changes Food frequency questionnaires administered to a subset of women Tissues analyzed by 2 pathologists independently Red blood cell fatty acids analyzed | Proliferative and non-proliferative fibrocystic disease and progression to breast cancer: tissue analysis in duplicate | Women in the highest quartiles of EPA erythrocyte concentration were 67% less likely to have nonproliferative changes alone or with breast cancer and 49% less likely to have breast cancer than women with proliferative changes (or than women in the lowest quartiles?). Total n-3 PUFAs and EPA were associated with a significant reduction in risk of NPFCs alone; total n-3s, EPA and DHA were associated with a significant reduction in risk of breast cancer in women with nonproliferative changes cf. controls. Ratio of palmitic to palmitoleic also associated with decreased risk for all conditions, suggesting δ-9 desaturase may be of greater importance than FA levels alone. Conclusion: n-3s in all forms associated with risk reduction, but evidence suggests indirect effect.
Shanghai Textile Industry Bureau cohort Shannon, 2007^60^ | Women born between 1925 and 1958, permanent residents of Shanghai from breast self-exam trial; 322 BC cases included | Case control Questionnaire completed between 1989 and 1991. Monitored through 2000 for breast changes Food frequency questionnaires administered to a subset of women Tissues analyzed by 2 pathologists independently Red blood cell fatty acids analyzed | Breast cancer dx confirmed at one of 3 hospitals used by the bureau | % n-3 PUFA associated with significantly lower risk of BC, primarily attributable to EPA. Data suggest importance of ratio of monounsaturated to saturated fatty acids Conclusions: n-3s decrease risk of BC
EPIC Engeset, 2006^61^ | 310,671 women aged between 25 and 70 yr | dietary questionnaire between 1992–98 Median followup of 6.4 yr | Ascertainment based on population cancer registries in Denmark, Italy, the Netherlands, Norway, Spain, Sweden, and the UK and on a combination of methods, including health insurance, cancer and pathology registries, and active follow-up through study subjects and their next-of-kin in France, Germany, and Greece | Hazard ratio for breast cancer by intake of total and lean and fatty fish were estimated, stratified by study centre and adjusted for established breast cancer risk factors. During follow-up, 4,776 invasive incident breast cancers were reported. No significant associations between intake of total fish and breast cancer risk were observed, hazard ratio (HR) 1.01 (95% confidence interval [CI] 0.99–1.02; p=0.28 per 10 g fish/day). When examining lean and fatty fish separately, we found a positive significant association only in the highest quintile for fatty fish (HR 1.13, 95% CI 1.01–1.26), but test for trend was not significant (p =0.10. No difference was seen between pre- and postmenopausal women Conclusions: no effect or positive effect of fish/fatty fish intake on BC risk
Japan Collaborative Cohort Study (JACC) Wakai, 2005^62^ | 26,291 women aged 40–79 years Participants were enrolled from 45 study areas throughout Japan, from general populations or participants in municipal health check-ups | Prospective cohort Questionnaire on dietary and other factors completed at baseline (1988 to 1990) Mean follow-up of 7.6 years | Ascertainment of the incidence of cancer by means of a linkage with the records of population-based cancer registries, supplemented by a systematic review of death certificates | 129 breast cancer cases were documented during followup period. Significant decrease in risk was detected for the highest quartile of intake compared with the lowest for fish fat and long-chain n-3 fatty acids; the RR were 0.56 (95% CI 0.33– 0.94) and 0.50 (0.30–0.85), respectively Conclusions: marine and non marine n-3s associated with decreased risk BC
Iowa Women's Health Study Cohort Folsom 2004^63^ | 41,836 women (55-69 yoa) recruited via baseline mailed questionnaire | Prospective cohort Single baseline 127-item FFQ used 4 questions to assess intakes (servings and frequencies) of 1) dark meat fishes (3-5 oz), 2) canned tuna (3-4 oz), 3) other fish (3-5 oz), 4) shrimp, scallops, or lobster (3.5 oz) and calculated average daily intake of omega 3s. No questions about fish oil. Assessment of cancer incidence and deaths for 11 years (using mailers and linkage to state-wide records) | Deaths, breast cancer incidence in relative risk | Baseline fish consumption was similar to that of most contemporary U.S. populations. Conclusion: Neither fish intake nor marine omega 3s intake were associated with incidence of breast cancer.
Malmö Diet Cancer (MDC) Cohort Wirfält, 2004^64^ | 17, 035 women born between 1923 and 1950 and living in Malmö in 1991. Potential participants were sent letters or joined spontaneously; for this analysis, only postmenopausal women were included (defined as women over 50, n=12, 039) Exclusion: prevalent breast or other cancer (except cervical cancer in situ or non-melanoma skin cancer); limited Swedish language skills | Nested Case control Diet hx obtained by interviewers using 7-day menu book completed by participants at home and a questionnaire assessing the previous year. Data entered into MDC food and nutrient database. Reproducibility and concurrent validity assessed previously Erythrocyte membrane n-3 values were measured in blood samples | Ascertainment of breast cancer by record linkage with Swedish Cancer Registry and Southern Swedish Regional Cancer Registry | 249 incident breast cancer cases, resulting in 237 case control sets (exclusion for other prevalent cancer) Dietary n-3s were positively correlated with erythrocyte membrane fatty acids but no difference was seen in erythrocyte FA from fish and breast cancer risk Conclusion: erythrocyte membrane n-3 FA not associated with BC risk
Summary for Breast Cancer: 8 new studies (>100% increase in number of studies) with more than 50% increase in number of participants, total. 1 pivotal study (by size) shows potential detrimental effect of fatty fish. Other smaller studies show decreases risk or no link.
Colorectal Cancer Original report identified 6 studies (6 cohorts): Fish consumption (4 studies): 1 study found decreased risk in highest vs. lowest quartile of fish intake in 1 study (n=14,727 women); other three studies found no effect (n=47,949 men; 3,111 men and women; 88,751 women) Total n-3 FA (1 study): Highest quartile of n-3s had nonsignificantly lower risk than women in lowest quartile (n=35,215 Caucasian women) Specific n-3s (1 study): No difference for any n-3 (n=61,483 Caucasian women)
Singapore Chinese Health Study Butler, 2009^65^ | 63,257 men and women recruited between April 1993 and December 1998, from permanent residents or citizens of Singapore aged 45–74 years, and who resided in government-built housing estates (most citizens reside in such housing) Inclusion: baseline interview/questionnaire completion Exclusion: prior cancer 61,321 enrolled | Prospective cohort Validated 165-item FFQ w/ 14 fish items, all known to be lean fish; intake corrected for energy intake | Ascertainment by record linkage of the cohort database with respective databases from the population-based Singapore Cancer Registry and the Singapore Registry of Births and Deaths | As of December 31, 2005, 961 incident colorectal cancers reported Hazard ratios for highest vs. lowest quartiles of marine n-3 and saturated fat consumption. Marine n-3 polyunsaturated fatty acid (PUFA) intake was positively associated with advanced disease (Dukes C or D) (HR = 1.33, 95% CI = 1.05–1.70, p for trend = 0.01), regardless of sex. The association with marine n-3 PUFAs was strongest among those with the shortest (≤5 years) duration of follow-up (HR = 1.49, 95% CI = 1.00–2.21, p for trend = 0.04). In contrast, we observed a small, albeit imprecise, inverse association with marine n-3 PUFAs for localized colorectal cancer among those with the longest duration of follow-up (>10 years) (HR = 0.62, 95% CI = 0.29–1.34, p for trend = 0.55)
Cancer Prevention Study-II Nutrition Cohort Daniel, 2009^66^ | 99,080 participants (43,108 men and 55,972 women) Population described here: Cancer 2002;94:2490 – 501 | Baseline questionnaire in 1992,1997, 1999, 2001, 2003, and 2005 1999: 152-item FFQ No questions about use of flax or fish oil, only dietary intake was considered. Queries regarding the frequency of seafood intake included canned tuna fish, dark-meat fish (mackerel, salmon, sardines, bluefish, and swordfish), other fish (cod, haddock, and halibut), shellfish (shrimp, lobster, scallops, and clams), and breaded fish (fish sticks, cakes, or pieces). | Reported cancers were verified through medical records, registry linkage, or death certificates | 869 incident colorectal cancer cases (452 men and 417 women) Ratio of total n-6 to total n-3 intake was not associated with colorectal cancer risk in either sex. Total n-6 intake was inversely related to colorectal cancer risk in men [multivariate relative risk (95% confidence interval) for highest to lowest quartile, 0.81 (0.61-1.07); Ptrend = 0.07], and α-linolenic acid, the primary contributor to total n-3 intake, was associated with increased risk in women for quartiles 2 through 4 versus the lowest quartile [relative risk (95% confidence interval), 1.50 (1.12-2.01), 1.40 (1.04-1.87), and 1.38 (1.02-1.85), respectively; Ptrend = 0.13]. In women, total n-6 and marine n-3 intake appeared to be associated with higher and lower risk, respectively, but associations were attenuated with adjustment for other risk factors
FISHGASTRO: Wageningen Netherlands and Norwich UK Pot, 2009^67^ | Individuals 18-80 recruited fr 2004-2007; 242 participants (216 completed) 3 sets inclusion criteria (3 difft groups): (1) those with hx of colorectal polyps; (2) those with dx of UC (inactive); (3) those w/ no macroscopic sign of colon disease (attended clinic for IBS, hemorrhoids, unexplained anemia, bowel complaints, or changes in defecation patterns); 10% participation rate (mainly due to unwillingness to increase fish intake or undergo add'l sig) Exclusion criteria: fish allergy, taking fish oil supplements; taking NSAIDS or aspirin, organ transplant recipients, receiving immunosuppressive therapy; Type 1 DM, increased risk infection | Multicenter RCT w/ 3 arms: 1) oil-rich fish group (2×150g salmon/wk); 2) lean fish group; 3) dietary advice group for 6 months. Patients given fish and asked to incorporate into diet in addition to any fish normally eaten. Compliance checked with food diaries, regular phone calls, and for the salmon group, serum n-3 VLC-PUFA concn. | Baseline and post-intervention colonoscopy and biopsy Histological confirmation of polyps Fasting blood cholesterol, vitamin D, selenium FFQ and food diary Primary outcome = crypt cell apoptosis and proliferation in colonic biopsy samples | Jadad score 3 (assessors but not participants blinded) Additional fish consumption of ~1.4 servings /wk (either oily or lean) over 6 months did not significantly change apoptotic and mitotic rates of the colon mucosa (i.e., proliferation, associated with risk for cancer) in a population of fish eaters
Physicians' Health Study Hall, 2008^68^ | See Hall, 2007 below | Prospective cohort study Fish intake assessed at 12-month followup using an abbreviated semiquantitative food-frequency questionnaire validated in a similar population. Asked about intakes of 4 types of fish 22-year followup | See Hall, 2007,68 | At 22-yr followup, 500 confirmed cases of CRC Fish intake was inversely associated with colorectal cancer risk [multi-variate relative risk (95% confidence interval) for highest versus lowest category, 0.60 (0.40–0.91); Ptrend = 0.01]. The inverse association was observed for both colon and rectal cancers. Findings for n-3 fatty acids were similar to those for fish; the multivariate relative risk (95% confidence interval) of total colorectal cancer for the highest versus lowest quartile of n-3 fatty acids was 0.74 (0.57–0.95; Ptrend = 0.01)
SOCCS (Study of Colorectal Cancer in Scotland) Theodoratou, 2007^69^ | 2910 cases and controls (1,455 each, males and females) prospectively recruited from 1999-2006 among all 16-79 year olds diagnoxed with adenocarcinoma of colon in Scottish hospitals Exclusion: death prior to ascertainmnt, being too ill to participate, case represented recurrence; inability to give informed consent | Case control study Semi-quantitative 150-item FFQ; health, lifestyle questionnaire/hx Fatty acid composition of food obtained from UK food composition tables and compared in cases vs. controls | Ascertainment in hospitals; recruitment within 2–3 mos of dx to limit survival bias | Multiple logistic regression models showed EPA, DHA, and EPA+DHA/ALA were inversely proportional to adjusted OR for developing colorectal cancer in dose-dependent manner. Relationships persisted even after adjustment for energy intake
Geelen, 2007^70^ | Meta-analysis of 19 prospective cohort studies (only 6 included in original omega 3s report – 11 clearly missed based on publication date; not sure why; possibly due to rejection at title stage due to apparent lack of relevance) two newer studies | Meta-analysis Pooled relative risks in highest vs. lowest category of exposure for fish intake and derived omega 3 fatty acids | Colorectal cancer incidence and mortality | Pooled relative risks for highest vs. lowest fish consumption category (14 studies): 0.88 (95% CI, 0.78, 1.00); for colorectal cancer mortality (4 studies): 1.02 (95% CI 0.90 1.16) For each extra occurrence of fish consumption/wk, pooled relative risk was 0.96 (0.92, 1.00) Effect more pronounced for women than men and in studies w/ larger difference between highest and lowest exposures
Physicians' Health Study Hall, 2007^71^ | 178 male participants diagnosed with CRC during followup (through 1995) 1-2 controls selected from unaffected members of cohort (with no cancer at time case reported cancer) for each case (104 cases had two controls), matched for age and smoking status | Nested case control using blood samples Annual followup questionnaires | Cases reported on annual questionnaires were followed up with patients' physicians | Total long-chain n-3 fatty acids were non-significantly inversely associated with CRC risk [relative risk (RR) for highest versus lowest quartile, 0.60; 95% confidence interval (95% CI), 0.32 to 1.11; Ptrend = 0.10], after adjustment for possible confounders. Potential interaction was seen between randomized aspirin assignment and long-chain n-3 fatty acid levels (Pinteraction = 0.04). Among men not on aspirin, RRs (95% CI) for increasing quartiles of long-chain n-3 fatty acids were 1.00 (reference), 0.60 (0.28-1.28), 0.51 (0.22- 1.17), and 0.34 (0.15-0.82), Ptrend = 0.006. For participants taking aspirin, there was no additional benefit of increasing n-3 fatty acid levels. RR (95% CI) for the highest versus lowest quartile of n-6 fatty acids was 0.64 (0.35-1.17) Conclusion: long-chan n-3 FA clearly decreased CRC in men not taking aspirin
EPICS (European Prospective Investigation into Cancer and Nutrition) Norat et al., 2005^72^ | 478,040 men and women (mostly age 35–70 years) from 23 centers in 10 European countries who were free of cancer at enrollment between 1992 and 1998. Participants were mostly recruited from the general population with the exception of a group of women teachers who were recruited through their health insurance pool in France and women in Utrecht who were recruited during breast cancer screening. Exclusion: prevalent cancer other than nonmalignant skin cancer; energy intake at the high or low extreme end | Prospective cohort study mean followup of 4.8 years Diet over the 12 months prior to enrolment was assessed using validated country-specific questionnaires. Fish included fresh, canned, salted, and smoked fish 8% random sample of the cohort (36 994) also received a detailed computerized 24-hour diet recall | Colorectal cancer incidence; ascertainment based on population cancer registries, except in France, Germany, and Greece, where a combination of methods, including health insurance records, cancer and pathology registries, and active follow-up of study subjects and their next-of-kin was used. Mortality data were collected from either the cancer or mortality registries at the regional or national level | 1329 incident colorectal cancers were documented Intake of fish was statistically significantly inversely associated with colorectal cancer risk (for highest versus lowest intake HR = 0.69, 95% CI = 0.54 to 0.88, Ptrend<.001). The trend for an inverse association was statistically significant for cancers of the left side of the colon (Ptrend = .02) and the rectum (Ptrend<.001), but not for cancers of the right side of the colon. The hazard ratios per 100-g increase in fish intake were 0.70 (95% CI = 0.57 to 0.87, Ptrend<.001) and 0.46 (95% CI = 0.27 to 0.77, Ptrend = .003) before and after correction. The association was statistically significant and similar for both colon and rectal cancers. Fish effect was not consistent across all centers. In this study population, the absolute risk of development of colorectal cancer within 10 years for a study subject aged 50 years was 1.86% for subjects in the lowest category of fish intake and 1.28% for subjects in the highest category of fish intake.
The JACC (Japan Collaborative Cohort Study for the Evaluation of Cancer Risk) Study Kojima, 2005^73^ | 65,184 of the 110,792 study participants living in 24 study areas with cancer registries. 169 incident colorectal cancer cases and 481 controls Exclusion: previous hx of cancer | Nested case control Relative risk of colorectal cancer development cf. quartiles of serum fatty acids | Case ascertainment used population-based cancer registries supplemented with death certificates | Total n-3s were inversely associated with colorectal cancer risk: Risk reduction 76% cf Q4 to Q1 (OR 0.24, 95% CI 0.08, 0.76) p for linear trend 0.08 In men: ALA: OR 0.39 (95% CI 0.16, 0.91) DPA: OR 0.30 (95% CI 0.11, 0.80) DHA : OR 0.23 (95% CI 0.07, 0.76) Link between DPA and cancer for women was weak and nonsignificant
Swedish Mammography Cohort Larsson, 2005^74^ | 61,433 women aged 40-75 years and free from diagnosed cancer at baseline in 1987-1990 | Cohort study FFQ Mean followup of 13.9 years, | Relative risk of colorectal cancer | Identified 234 proximal colon cancers, 155 distal colon cancers and 230 rectal cancers. No association was seen with fish intake and CRC at any site in the colon
Women's Health Study Lin, 2004^75^ | 39,876 women ≥45 recruited beginning in 1993 Exclusion for this analysis (2,329): provision of inadequate dietary information at baseline, implausible total energy intake , or lack of information on potential risk factors at baseline 202 incident cases over 8.7 years among the 37,547 participants | Cohort based on WHS RCT (a trial of low dose aspirin and vitamin E) 131-item FFQ Followup questionnaires every 6 months for 1 year and yearly thereafter Intakes of dietary fat and fatty acids were categorized into quintiles | Medical records and pathology reports for incident cases and reported deaths | Multivariate analysis, Cox proportional hazards regression used to estimate relative risks. No association was seen between intakes of any type of fat (including n-3s) and total fat and risk for colorectal cancer in these women (however intake of fried foods showed some association)
Summary for CRC: 8 new studies with more than 50% increase in number of participants, total. Some studies supported finding of decreased risk with increased fish intake. New support for decreased risk with individual n-3s.
Lung Cancer: Original report identified 3 studies (3 cohorts) that assessed effect of n-3s on incidence and 1 that assessed effect on mortality 1 study found decreased risk with highest vs. lowest tertile fish intake; other studies found no effect of higher fish consumption on incidence or death No new findings
Lymphoma: Original report identified 2 studies (2 cohorts) on incidence of non-Hodgkins lymphoma (NHL) Fish intake:1 study found no effect of increasing fish consumption (35,156 women) Total n-3s: 1 study found no effect of increasing intake of n-3s (as % total caloric intake) (88,410 women)
Scandinavian Lymphoma Etiology (SCALE) study Chang, 2006^76^ | Newly diagnosed malignant lymphoma patients and controls in Sweden and Denmark Dietary study involved residents 18-74 yoa of 7 Swedish counties (10/00-4/02) Inclusion: no hx of organ transplantation, human immunodeficiency virus infection, or prior hematopoetic malignancy; ability to communicate in Swedish; first, incident morphologically verified dx NHL (811 cases/686 consented to participate/614 completed diet questionnaire); controls (576 of 718/492 completed diet questionnaire) were identified in general population by computerized register (New sample every 6 months matched to expected 10-year age group and sex of cases | Population-based case control study Semi-quantitative validated FFQ measured average daily consumption of total omega 3s and marine fatty acids | Rapid case ascertainment system established for this study w/ backup of nationwide cancer registry | Dietary intake of omega 3s or marine fatty acids was associated with decreased risk NHL and chronic lymphocytic leukemia. Comparing highest and lowest quartiles of marine fat intake, OR for NHL risk was 0.6 (95% CI, 0.4, 0.9)(ρ trend=0.03)
Ovarian Cancer Original report identified one study that assessed the effect of various kinds of fat, including n-3s, on incidence and found no effect No new studies found
Pancreatic Cancer Original report identified two studies (two cohorts) Fish consumption (1 study): no significant effect of fish consumption (27,111 men) Total n-3 consumption (1 study): no effect of n-3s ALA (2 studies): no effect of ALA )27,111 men; 88,802 women) No new studies
Prostate Cancer: Original report identified 7 studies (5 cohorts) Fish consumption (4 studies): 1 study showed inverse effect (6,272 men); one study showed positive effect (14,000 7^th^ day Adventists); other two studies (total 56,763) showed no effect Marine n-3s (1 study): no effect found (47,855 health professionals) DHA and EPA (two studies): no effects seen (approx. 108,000) ALA (3 studies): increased risk for advanced cancer but not overall (47,866) in one study; no significant effect in the other (58,279) (data missing for 3^rd^)
Simon, 2009^77^ | 16 studies assessing effect of ALA on risk for prostate cancer; studies that compared highest and lowest quintiles were pooled | Systematic Review of studies that reported ORs, RRs, or relative hazards and 95% CIs | Prostate cancer / ascertainment unclear | Studies suggested a slight increase risk for prostate cancer with increased ALA. New studies, retrospective case control studies, and studies that assessed ALA intake by inferring from blood levels tended to identify a small effect whereas older studies, prospective cohort, and dietary assessment studies tended to see no effect.
Physician's Health Study Chavarro, 2008^78^ (earlier version included in Simon MA77) | 22,071 male physicians aged 40-84 enrolled in 1982 in a trial of aspirin and beta carotene to prevent heart disease and cancer. 2,161 men were dx w/ prostate ca during the followup. Excluded from analysis were men who did not repot fish intake or who died or reported a cancer Dx prior to the 12-month followup period. Men were followed until date of cancer dx, death, or end of followup (3/1/06), whichever came first. | Prospective study of fish intake using trial population. 12-month Questionnaires (abbreviated FFQ) assessed average intake of 4 classes of fishes over previous year but did not allow estimation of total energy intake Fish and seafood n-3 FA intakes were also corroborated with blood EPA and DHA in 436 members of cohort (controls) | Dx ascertained and stage, grade, etc. confirmed by hospital records and pathology reports. Most cases initially dx by PSA screening. | Total fish intake as well as specific types of fish intake (except “Other”) were unrelated to prostate cancer dx (incidence). This lack of relationship was not affected by baseline BMI or assignment to aspirin or beta carotene treatment. However, among those who died, baseline fish intake was inversely related to prostate cancer mortality for all types of fish except shellfish, even after omitting those diagnosed by PSA (men assumed to be more health conscious and detected early).
Physicians' Health Study Chavarro, 2007^79^ (included in Simon MA77) | See above | Nested case control among 14,916 apparently healthy men; whole blood levels of PUFAs determined in 47 men diagnosed with PC during 13-year followup and matched controls | Total PC, stage (nonaggressive, aggressive, subsequent metastases, death) | Whole blood levels of all LC n-3 FA (mainly found in marine foods) were inversely correlated with overall risk of PC (RR quintile 5 vs. 1=0.59 [0.38, 0.93], p trend=0.01); linoleic acid was also inversely related ALA was unrelated to PC risk
European Prospective Investigation into Cancer and Nutrition (EPIC) Crowe, 2008^80^ | 962 men dx w/ prostate cancer after median followup time of 4.2 yrs and 1,061 matched controls participating in EPIC | Nested case control analysis Validated FFQ | Population-based cancer registries in 6 of the participating countries; in Germany and Greece, followup was via self-completed questionnaire and medical records | Plasma levels of EPA and ALA were positively associated with risk of high-grade prostate cancer but relationship between EPA, DHA, and ALA and risk of prostate cancer in general were not significant
European Prospective Investigation into Cancer and Nutrition Crowe, 2008^81^ | After median followup of 8.7 years, 2,727 men dx w/ prostate cancer in EPIC. | Nested case control analysis Validated FFQ | Population-based cancer registries in 6 of the participating countries; in Germany and Greece, followup was via self-completed questionnaire and medical records | Age-standardized PC incidence differed 6-fold by country (Sweden highest; Greece lowest) Fat intakes differed × 11%. No relationship was seen between intake of any type of fat (total, PUFA, MUFA, saturated, P/S ratio, red and processed meat, dairy, fish) and prostate cancer incidence
Multiethnic Cohort Study Park, 2007^82^ (included in Simon MA77) | >215,000 men and women in L.A. and Hawaii ≥45 yoa in original study 82,483 men in this analysis Inclusion: membership in 1of 5 ethnic groups Exclusion: previous prostate cancer Dx, invalid dietary information, missing information on height, weight, educational level, smoking status | Prospective cohort Questionnaire on diet and health history | Incident cases identified by linkage to 3 SEER-linked cancer registries | Overall, study found no evidence for a link between total n-3s, ALA, DHA, EPA and prostate cancer link. Trend toward a protective effect of total n-3s on prostate cancer in Latino and white men but not blacks or Japanese Americans
Miyoko Study Pham, 2009^83^ | 5,589 men aged 30–79 years in 4 areas of Fukuoka Prefecture Japan. Enrollment was from ′86-′89 and men followed to ′99 or ′03 | Prospective cohort study FFQ used to classify participants into low and high fish intake (Fish intake was assessed at the five levels of ‘twice or more per day’, ‘once a day’, ‘2–4 times per week’, ‘2–4 times per month’ and ‘seldom or never’. For the present analysis, consumption levels were converted into two groups by combining the ‘2–4 times per month’ and ‘seldom or never’ groups into a new ‘low intake’ group; and the ‘twice or more per day’, ‘once a day’ and ‘2–4 times per week’ groups into a ‘high intake’ group) | Risk of death from prostate cancer; ascertainment from death certificates | Cox proportional hazards model Consistent inverse association of this cancer with higher intakes of fish. The multivariate model adjusted for potential confounding factors and some other food items showed a HR of 0.12 (95% CI 0.05, 0.32) for the high intake group of fish consumption.
Cancer Prostate in Sweden (CAPS) Hedelin, 2007^84^ (Included in Simon MA77) | Swedish men age 35–79 | Case control study 261-item validated FFQ | National Prostate Cancer Registry | 1,130 controls, 1,499 cases Dietary marine n-3s from fatty fish associated with decreased risk PC (OR for fatty fish ≥1/week vs. never 0.57 CI 0.43, 0.76; OR highest vs. lowest quartile marine FA 0.70, CI 0.51, 0.97) Significant interaction with small nuclear polymorphism in COX-2 gene (key enzyme in eicosanoid synthesis, over-expressed in PC tissue) but not with 4 other SNPs
PLCO Cancer Screening Trial Koralek, 2006^85^(Included in Simon MA77) | 29,592 eligible men primarily Caucasian Exclusion: previous history of cancer except melanoma, incomplete baseline and dietary survey information | Prospective cohort study 137-item semi-quantitative FFQ | PSA screening results and annual questionnaires were followed up with medical record reviews as well as review of pathology/autopsy reports, | 1,898 cases of prostate cancer (1,631 organ-confined and 285 advanced stage); ALA intake was not associated with overall risk for prostate cancer (multivariate RR for highest vs. lowest quintiles: 0.94 (0.81, 1.09), organ confined or advanced prostate cancer. Also, ALA from specific foods was not associated with prostate cancer risk.
Bidoli, 2005^86^ (Included in Simon MA77) | 1,294 Italian men with prostate cancer in 5 areas of Italy Controls were 1,451 male inpatients admitted to same hospitals for conditions unrelated to malignancy or dietary modification | Case-control study Health questionnaire included FFQ | Histological ascertainment by major regional teaching or general hospital | Multiple logistic regression models showed that highest quintile of ALA consumption was associated with a lower risk of PC compared with the lowest quintile(OR 0.7, 95% CI 0.6, 0.9) and a significant trend with increasing consumption, but decreasing ALA risk was also associated with increasing linoleic acid (n-6) consumption.
Summary for Prostate Cancer: 9 new studies (7 cohorts) and MA suggests need for update. Findings remain contradictory with some showing positive, some negative, and some no association
Renal Cancer No studies in original report
Alpha-Tocopherol Beta-Carotene Cancer (ATBC) Prevention Study (Finnish cohort of smokers) Wilson, 2009^87^ | 228 renal cell CA cases diagnosed among 27,111 Finnish males who smoked ≥5 cigarettes/d and or whom dietary information was available Exclusion: prior cancer Hx except nonmelanoma or carcinoma in situ; severe exertional angina, chronic renal insufficiency, cirrhosis of the liver; alcoholism, anticoagulant use, vitamin E (>20mg/d), vitamin A (>20,000IU/d), beta-carotene (>6mg/d) or other problems perceived to limit participation over 6 years | Original design RCT of vitamin A supplementation and lung cancer/Nested case control (?) Baseline self-administered FFQ assessed intake of frozen fish, rainbow trout, Baltic herring, other fresh fish, canned/salted fish | Renal cell cancer/ascertained by ATBC and Finnish cancer registry dual record review | Hazard (risk) ratio for RCC was not associated with intakes of any fish except Baltic herring; highest quartile of intake was associated with increased risk of RCC
Swedish Mammography Cohort Wolk, 2006^88^ | Of 66,651 women who completed the baseline questionnaire, 150 incident cases of renal cell carcinoma (RCC) dx in 15.3 mean yrs followup | Validated 67-item FFQ at baseline and 96-item FFQ in 1997 asked about servings per week of fatty fish, lean fish, and other seafood (shellfish) | Ascertainment through computerized linkage with national and regional cancer registers | In age-adjusted and multivariate analyses, fatty fish consumption of ≥1 serving/week was associated with a significant 44% decreased risk of RCC. No association was found for lean or other fish. Sensitivity analysis was carried out for decades of followup. Women who consistently reported long-term consumption of ≥1-3 servings of fatty fish/month at baseline and 10 yrs later had a 74% lower risk of RCC cf. no consumption.
Skin Cancer: Original report found 1 study that looked only at basal cell carcinoma. Highest n-3 consumption associated with small but significantly increased risk of BCC relative to lowest quartile. (43,217 health professionals)
Community-based study in Australia Hughes, 2009^89^ | Randomly selected group from among 1,621 adult participants in a skin cancer prevention trial Exclusion: at least 1 indeterminate actinic keratosis (AK), answering <90% FFQ, energy intake outside the normal limits | RCT cf beta-carotene supplementation and sunscreen Validated 129-item FFQ administered in '92, '94, '96 (participants chose one of 9 responses [never-4+times/d] for how often they'd eaten a given amount of each of the foods) | Outcome was AK (pre-malignant skin tumors/lesions) assessed by experienced dermatologists at 14 separate body sites (cts>50 called indeterminate) | Strongest association between food and AK was that for oily fish. Between 1992 and 1996, AK increased by 95% in those with the lowest intakes , 45% among those with intermediate intake (1serving/2 weeks, on average), and 41% among those with the highest (fully adjusted) intakes (1 serving/5 d). Prevalence decreased by 26% and 28%, respectively. Sensitivity analysis looking only at those without daily sunscreen use found that AK acquisition was not related to intermediate level of oily fish intake, but high oily fish intake remained strongly (negatively) associated with AK acquisition (RR: 0.66, 95%CI, 0.45, 0.98)compared with the lowest intake
Stomach Cancer: Original report identified 1 study that assessed risk relative to fish consumption and found no effect. No new studies
KQ 1B: If omega-3 fatty acides influence the incidence of tumors, is there an inverse relationship with intake?
Original report identified the following dose effects Breast cancer: dose effects for marine n-3s and ALA; no dose effects for fish, total n-3s, DHA, EPA Colorectal cancer: dose effects tested but not observed Lung cancer: study that reported reduced risk of CA reported dose effect Lymphoma: dose effects tested but not observed Ovarian cancer: no dose effects observed Pancreatic cancer: dose effects tested but not observed Prostate cancer: Dose effects tested in all 7 studies. Dose effects seen for fish in two of four studies, but in opposite directions. Dose effects seen for ALA in two studies but in opposite directions. No dose effect seen for EPA, DHA, total n-3s. Skin cancer: Study found increased risk with increasing dose. Stomach cancer: dose response assessed but not seen
SOCCS (Study of Colorectal Cancer in Scotland) Theodoratou, 2007^69^ | 2910 cases and controls (1,455 each, males and females) prospectively recruited from 1999-2006 among all 16-79 year olds diagnoxed with adenocarcinoma of colon in Scottish hospitals Exclusion: death prior to ascertainmnt, being too ill to participate, case represented recurrence; inability to give informed consent | Case control study Semi-quantitative 150-item FFQ; health, lifestyle questionnaire/hx Fatty acid composition of food obtained from UK food composition tables and compared in cases vs. controls | Ascertainment in hospitals; recruitment within 2–3 mos of dx to limit survival bias | Multiple logistic regression models showed EPA, DHA, and EPA+DHA/ALA were inversely proportional to adjusted OR for developing colorectal cancer in dose-dependent manner. Relationships persisted even after adjustment for energy intake
The JACC (Japan Collaborative Cohort Study for the Evaluation of Cancer Risk) Study Kojima, 2005^73^ | 65,184 of the 110,792 study participants living in 24 study areas with cancer registries. 169 incident colorectal cancer cases and 481 controls Exclusion: previous hx of cancer | Nested case control Relative risk of colorectal cancer development cf. quartiles of serum fatty acids | Case ascertainment used population-based cancer registries supplemented with death certificates | Total n-3s were inversely associated with colorectal cancer risk: Risk reduction 76% cf Q4 to Q1 (OR 0.24, 95% CI 0.08, 0.76) p for linear trend 0.08
KQ 1c: Is there a temporal relationship with intake? The original report identified no studies that answered this question, and no new studies were identified that addressed this question.
KQ1d: What is the evidence that genes involved in omega-3 fatty acid transport or metabolism influence the magnitude or direction of the influence on tumor incidence? The original report identified no studies that answered this question.
Cancer Prostate in Sweden (CAPS) Hedelin, 2006^84^ (Included in Simon MA77) | Swedish men age 35–79 | Case control study 261-item validated FFQ | National Prostate Cancer Registry | 1,130 controls, 1,499 cases Dietary marine n-3s from fatty fish associated with decreased risk PC (OR for fatty fish ≥1/week vs. never 0.57 CI 0.43, 0.76; OR highest vs. lowest quartile marine FA 0.70, CI 0.51, 0.97) Significant interaction with small nuclear polymorphism in COX-2 gene (key enzyme in eicosanoid synthesis, over-expressed in PC tissue) but not with 4 other SNPs
KQ2 Key Question 2: Effects on Clinical Outcomes after Cancer Treatment Key Question 2a: What is the evidence that omega-3 fatty acids alter the effects of cancer treatment on malignant tumors and clinical outcomes after cancer treatments?
Response to Chemotherapy No studies in the original report assessed this outcome.
Bougneaux, 2009^23^ | 25 breast cancer patients with rapidly progressing visceral metastases that were not amenable to hormonal therapy or alternative treatment and without earlier chemotherapy for metastases Exclusion: history of any other cancer (with the exception of non-melanoma skin cancer or cervical carcinoma in situ), bilateral (without other metastatic location) or inflammatory breast cancer. | Phase II trial (open label single arm) testing effect of DHA on response of metastatic BC patients to chemotherapy (1.8g/d DHA of algal origin given as 9 capsules (3at each meal)(DHA is thought to sensitize cancer cells to chemo) DHA was administered from inclusion before initiation of chemotherapy (a 7–10-day loading period) and then for the 5 months of chemotherapy. Patients were asked to avoid antioxidant supplements | Primary outcome: Assessment of tumor response rate (clinically and radiographically), AE assessment Secondary outcome: time to progression (TTP) and overall survival (OS) Incorporation into plasma was also measured | Objective response rate was 44%. With a mean follow-up time of 31 months (range 2–96 months), the median TTP was 6 months. Median OS was 22 months and reached 34 months in the sub-population of patients (n=12) with the highest plasma DHA incorporation. The most common grade 3 or 4 toxicity was neutropaenia (80%). Conclusion: DHA improved outcome of chemotherapy for metastatic breast cancer
Sydney AUS 2 hospitals Read, 2007^22^ | 23 Colorectal cancer patients receiving chemotherapy (5 FU, irinotecan, folinic acid) with one prior cycle of chemo | Phase II trial testing effect of EPA-containing supplement 480ml/d for 3wks before resuming 3 3-wk cycles chemo | BW, body comp, CRP, QOL, dietary intake, PPL, and cytokines | 20 patients completed 3 weeks and 15 completed 9 weeks. BW increased, LBM was maintained. Although protein and E intake decreased, perceived energy levels increased. CRP increased but returned to baseline levels by end of 9 weeks. Conclusion: EPA may help maintain nutritional status and QOL but RCTs needed
Response to Surgery Original report assessed Post-op complications, length of stay, mortality, nutritional parameters (nitrogen intake, calorie intake, albumin, transferrin, prealbumin), and Weight after surgery for upper GI malignancy resection Post-operative complications assessed in 14 studies (3 studies of n-3s alone and 11 studies of n-3s + arginine): Pooled random effects estimate for 3 studies of n-3s alone: 1.19 (0.66, 2.13) Pooled random effects estimate for n-3s + arg: 0.51 (0.40, 0.64) Pooled random effects estimate for all 14 studies: 0.57 (0.46, 0.71) Length of Stay (LOS) assessed in 13 studies (3 for n-3s alone and 10 for n-3s + arg): Pooled random effects estimate of LOS difference for 3 studies of n-3s alone: 1.09 days (-3.63, 5.81) Pooled random effects estimate for n-3s + arg: -3.33 days (-4.29, -2.38)) Pooled random effects estimate for all 13 studies: -3.17 (-4.11, -2.26) Mortality assessed in 10 studies (4 for n-3s alone and 6 for n-3+arg) Pooled random effects estimate for 4 studies of n-3s alone: 1.42 (0.63, 3.38) Pooled random effects estimate for n-3s + arg: 1.01 (0.31, 3.35) Pooled random effects estimate for all 14 studies: 1.25 (0.64, 2.48) Nutritional parameters: 11 studies assessed effects of n-3s alone or in combination with arg and RNA on various nutrition metrics Of 6 studies, no significant effect seen on caloric intake; 1 study found an increase in N intake, and 1 found no effect; of 6 studies that assessed serum albumin and 3 that assessed transferrin, no effects were found; 2 of 6 studies that assessed prealbumin found significant increases in treated groups. Of 3 studies that assessed weight (loss), 1 showed less weight loss, one showed no difference, and one showed greater weight loss with n-3s.
Trinity College Hospital, Ireland Ryan, 2009^19^ | 53 esophagectomy patients | RCT cf EN (25 pts) with EN enriched with 2.2g EPA/d (28 pts) for 5d preop (oral) and 21d post-op (jejunal) | Esophageal/Bioimpedance, post-op complications, acutephase response, coagulation markers, serum cytokines | EPA significantly increased peripheral blood mononucleocyte (PBMC) EPA levels but did not affect incidence of major post-op complications. EPA improved retention of FFM (leg, arm, trunk) cf EN grp and attenuated stress response for TNF- α, IL-1-, IL-8
Okamoto, 2009^18^ | 82 consecutive patients who underwent surgery for gastric carcinoma, of whom 60 met the inclusion criteria: Exclusion: unresectable neoplasm, pervious abdominal radiotherapy, post-op chemotherapy; pulmonary, CV, hepatic, or renal disease; HX recent immunosuppressive therapy or immunological disease; ongoing infection; emergency operation; preoperative evidence of widespread metastatic disease or stenotic lesions | RCT cf. IMPACT (arg+RNA+n-3s) and isocaloric conventional formula (MEDIF) preop for 7 days; same post-op diet | Post-op complications: wound infection, resp tract infection, intra-abdominal bleeding, anastomotic stenosis, cardiac dysfunction, systemic inflammatory response syndrome (SIRS); immune parameters; body weight, Hgb, prealbumin, albumin, transferrin, RBP, total cholesterol, triglyceride, cholinesterase, Cu, Zn | Post-op infection rate and Req for post-op antibiotics sign decreased in IMPACT patients (7% vs. 28% and 3/30 vs. 10/30, respectively) SIRS duration significantly shorter in IMPACT group Length of hospital stay and weight loss did not differ between groups
5 Beijing hospitals Jiang, 2010^15^ | 206 patients with GI (60) or colon cancer (64) or other cancer (79), ages 18-70, undergoing surgery (final n=203) Exclusion:DM, abnormal lipid metabolism, renal dysfunction, liver dysfn, splenectomy, body temp>37.5C, concurrent hormone therapy, pregnancy | RCT of parenteral nutrition supplemented with Intralipid (soybean oil, giving a n-3/n-6 ratio of 1:7) vs. fish oil (n-3/n-6 1:3), isonitrogenous, isocaloric; 20-24h/d; 8 days post-op | No. post-op infections, occurrence of SIRS (systemic inflammatory response syndrome) during d1-7; length of hospital stay, costs | Fish oil associated with significantly fewer infectious complications on post-op d. 8: 12 vs. 4 Fish oil significantly decreased incidence of SIRS from 13/103 in the control group to 4/100 in the treated group.(p=0.039) Fish oil significantly decreased mean length of hospital stay from 17 to 15 days (p=0.041) Median weight loss in fish oil group was 1 kg (vs. 1.5 kg in controls) No serious adverse events: 1 instance of polyhydrosis and flushing in a control; small variations in body temp, respiratory rate, pulse, BP, liver and renal fn, blood lipids and glucose comparable in both groups
Liang 2008^21^ | 42 patients undergoing radical colorectal resection for CRC w/indication for post-op TPN | RCT total parenteral nutrition supplemented with either soybean oil (LCT; Intralipid, Fresenius-Kabi, SO group, n = 21) or a combination of omega-3 fish oil and soybean oil (LCT:fish oil = 5:1, fish oil; Omegaven, Fresenius-Kabi, FO group, n = 21), up to a total of 1.2 g lipid/kg per day for 7 d postoperatively. Placebo and active tx were isocaloric and isonitrogenous | Routine blood test, biochemistry, systemic IL-6 and TNF-α; percentage of CD3+, CD4+, and CD8+ Lymphocytes: preop, post-op d 1 and 8. Patient outcome included mortality during the hospital stay, length of post-op hospital stay, and infectious complications | FO modulated immune response and lowered inflammatory response but no statistical difference in actual infectious complication rate. LOS non-significantly shorter in FO group (17.45 ± 4.80 d vs. 19.62 ± 5.59 d, P = 0.19). No statistically significant difference in mortality (no deaths in either group)
DeLuis, 2008^14^ | 73 ambulatory postsurgical patients with oral and laryngeal cancer (without recent weight loss) Exclusion: severe renal and hepatic dysfunction, ongoing infection, fever in preceding month , major GI disease, autoimmune disorder, steroid treatment, and medication that could modulate weight or metabolism | RCT Randomization to two cans/day of n-3fatty acid (EPA+DHA)-enhanced (Grp 1 n-3/n-6=3.7 or n-6/n-3=0.27) vs. Grp. 2 (n-3/n-6=0.99 or n6/n3=1.01) | Oral and laryngeal cancer/Ascertainment?/ BW, body mass, post-op complications, prealbumin, albumin, transferring, lymphocytes Ascertained adherence via measurement and diaries | Duration of supplementation 85.8±26 vs. 88.9± 22.6. Post-op infectious complications were non-significantly higher in group 1. No difference between groups in any nutritional parameter; all were higher than baseline levels.
Japanese hospital Sakurai, 2007^20^ IMPACT IEEF (article does not state that formula contains n-3s) | 30 patients with esophageal carcinoma who underwent radical esophagectomy jejunostomy | RCT cf Ajinomoto IMPACT IEEF to regular polymeric enteral formula perioperatively (3 days preop, 1000 cal/d) and post-op approx 14d, 250 cal/d increasing progressively) | Esophageal Ascertainment unclear Pre- and post-op serum total protein, serum albumin, peripheral white blood cell count, % lymphocyte fraction, total lymphocyte count, IGF-1, thransthyretin, transferrin, retinol binding protein, serum DHLA, DHA, EPA, AA, various immunological parameters, post-op complications, hospital stay | No differences were seen in SIRS, resumption of normal feeding, post-op LOS, or post-op complications; IMPACT increased total lymphocyte count at 3 and 5 d post-op and a shift toward B cell proliferation.
Lobo, 2006^16^ | 120 patients undergoing resection for upper GI cancers, 30-80 yrs Exclusion: metastatic or unresectable disease, pregnancy, use of immunosuppressives | RCT Jejunostomy feeding (PN) with Stresson (n6/n3=3.45:1+arginine 9g/1250 cal) or Nutrison high protein (n6/n3=5:1+arg 3g/1250 cal) | Cancer of the pancreas, esophagus, stomach/ Post-op complications, non-infectious complications, mortality, duration of hospital stay, albumin, CRP, Hgb, white cell ct | No significant differences between groups in infectious post-op complications, albumin, CRP, white cell count, Hgb Short and long term survival (mortality) were the same: 6 deaths in each group
Japanese Hospital Aiko, 2005^90^ | 28 Patients w/ esophageal carcinoma who underwent surgery Exclusion: presurgical chemo or radiotherapy, ligated or resected thoracic duct, longerm fasing, Type 1 DM, renal or hepatic failure, previous use of corticosteroids or other immunosuppressants, | RCT Randomization to post-op enteral feeding with standard formula (Ensure w/ n-6 to n-3 ratio of 44, EN) or similar formula supplemented with oils to give a n-6 to n-3 ratio of 3 (RAC). All pts received parenteral mixture also. | Esophageal/ Ascertainment? Markers of coagulation and fibrinolysis, concn IL-6, 8; 6-keto-PGF-1α | Compared to EN (low n-3), RAC (higher n-3) decreased inflammation, including attenuating the normal post-op decrease in platelet count, platelet aggregation, coagulation activity, and cytokine production
DeLuis, 2005^17^ | 65 ambulatory post surgical patients with oral and laryngeal cancer and recent weight loss Exclusion: severe renal and hepatic dysfunction, ongoing infection, fever in preceding month , major GI disease, autoimmune disorder, steroid treatment, and medication that could modulate weight or metabolism | RCT of supplements: Grp 1 received n-6/n-3= 0.27(n-3/n-6=3.7/1), no supplemental arg vs. Grp. 2: n-6/n-3=0.92 (n-3/n-6=1.09) + arg | See DeLuis 2008 | Post-op infectious complications and weight stabilization were similar in both groups. No difference between groups in any other parameter; all were higher than baseline levels.
Snyderman, 1999^91^ | 136 patients with stage II-IV squamous cell carcinoma of the oral cavity, larynx, pharynx undergoing surgery to cure and in need of post-op supplementation | RCT of IMPACT cf. standard formula for at least 7 days | Change in BW, lab evaluations of nutritional status, infectious and wound healing complications, duration of hospitalization | IMPACT was associated with a significant decrease in post-op infectious complications; no significant difference in wound healing, LOS. Serum albumin was higher in IMPACT recipients Confirms earlier findings

* Trial name if named trial

# Gender, age (number)

## Cardiovascular Risk Factors

Table C3 Effects of omega-3 fatty acids on cardiovascular risk factors – new study data

Report Findings/Conclusions^*^ | Article | Design (interv) | N | | Study Findings | Data^#^
Original Key Questions (abbreviated and rephrased) What is the effect of omega-3 fatty acids (EPA, DHA, ALA; fish; supplements or dietary) on cardiovascular risk factors and intermediate markers of cardiovascular disease (see list of outcomes below)? How do the effects differ by; - Dose; - Duration of intake; - Specific omega-3 fatty acid (or their ratios); - Source (e.g., dietary fish, dietary oils, dietary plants, fish oil supplement, flax seed supplement); - Ratio of omega-6 to omega-3 fatty acids; - Population (men, premenopausal women, postmenopausal women, different age groups); - Baseline dietary intake of omega-3 fatty acids; - Presence of potential confounders; ○ Body mass index; ○ Blood pressure; ○ Medications; - Pre-existing conditions; ○ Diabetes; ○ Hypertension; ○ Hyperlipidemia; ○ Known cardiovascular disease; Are the effects sustained after the intervention or exposure stops?
| | | | | | | Net effect
Total cholesterol (TC) 23 RCTs (20 FO, 4 ALA) (N≥60 [parallel design], N≥40 [crossover]); 1. The studies “were heterogeneous, but mostly found small (0% to 6%), nonsignificant net increases in level of [total cholesterol].”; 2. “The effect of plant oils (ALA) on [TC] was possibly weaker but similar to the effect of marine oils.”; 3. 19 fish oil (FO) studies: Summary net effect 0 (95% CI -1, +2) mg/dL [μ=0.4257; SE=0.9537]; Higher mean baseline TC associated with larger net decrease in TC.[1]; 4. 5 ALA studies: Range of net effects -1, +13 mg/dL[2]; 5. No clear evidence of different effects in different populations; 6. Inadequate or inconsistent evidence regarding covariates, dose, source, or type of n-3 FA; 7. No difference in effect seen across 5 weeks and 2 years of exposure.; 8. No evidence on sustainment of effect. | Pan, 2009^92^ | Meta-analysis (flaxseed) | 1548 | Non-sig. decrease in TC. Note: this includes lignans (0g ALA) intervention for 181 patients. | | | -0.10 mmol/L (-0.20, 0.00)
| Pan, 2009^92^ | Meta-analysis (flaxseed) | Varies | Meta-regression analysis showed that sex, type of intervention (whole flaxseed, flaxseed oil, or lignan supplement (0g ALA)), study quality (Jadad score), and initial lipid concentrations influenced the net change in TC. | | | -0.19 (-0.29, -0.09) Whole flaxseed studies
| Pan, 2009^92^ | Meta-analysis (flaxseed) | Varies | | | | +0.06 (-0.07, 0.19) Flaxseed oil studies
| Pan, 2009^92^ | Meta-analysis (flaxseed) | Varies | | | | -0.24 (-0.36, -0.12) Female studies
| Pan, 2009^92^ | Meta-analysis (flaxseed) | Varies | | | | +0.09 (-0.05, 0.23) Male studies
| Oikawa, 2009^26^ (JELIS) | RCT (EPA supplement) | 14,080 | Among those with normoglycemia, sig lower final TC with EPA (not clinically relevant) | | | Estimated: -2 (-2.9, -1.1) [SE 0.46] -1.5 (-2.4, -0.7)
| Oikawa, 2009^26^ (JELIS) | RCT (EPA supplement) | 4565 | Among those with impaired glucose metabolism, sig lower final TC with EPA (not clinically relevant) | | | Estimated: -1 (-2.8, 0.8) [SE 0.90] [image]
| Saitio, 2008^93^ (JELIS) | RCT (EPA supplement) | 957 | For high-risk group (TG ≥150 mg/dL and HDL-C <40 mg/dL), no sig effect on TC. | | | Estimated: +1 (-3.27, 5.27)
| Hjerkinn, 2005^94^ | RCT: 2×2 factorial (Dietary counseling, 2.4g/d n-3 PUFA) | 281 | 2.4 g/d n-3 in treatment group with no diet intervention in both groups produced a non-sig. reduction in TC. | | | -0.1 (-0.38, 0.18)
| Hjerkinn, 2005^94^ | RCT: 2×2 factorial (Dietary counseling, 2.4g/d n-3 PUFA) | 280 | 2.4 g/d n-3 in treatment group with diet intervention in both groups produced a non-sig. reduction in TC. | | | -0.2 (-0.46, 0.06)
| Caslake, 2008^95^ (FINGEN) | Randomized, dose-response, cross-over (FO supplement 0.7 or 1.8 g EPA+DHA/d) | 312 | Both 0.7 and 1.8 g FO dose groups had no sig. effect on TC, and there was no sig. dose effect. | | | Net diff cannot be estimated because the SE for all 3 groups was the same due to crossover design
| Grundt, 2003^96^ | RCT (FO supplement ~2g EPA+DHA/d) | 246 | No sig. effect on TC | | | Estimated: -0.24 (-0.54, 0.06) mmol/L
| Griffin, 2006^97^ (OPTILIP) | RCT (6%of kcal from PUFAs with an n6:n3 of 10:1 (control), 5:1 when the n3 fatty acids were predominantlyα-linolenic acid (18:3n3), 3:1 when the n3 fatty acids were predominantly long-chain n3 PUFAs (EPA and DHA), or both α-linolenic acid and long chain n3 PUFA) | 258 | No sig. effect on TC | | | Estimated: n3 LC PUFA: 0.16 (-0.21, 0.53) High α-linolenic acid: 0 (-0.39, 0.39) N3 LC PUFA + α-linolenic acid: 0.07 (-0.32, 0.46) Moderate α-linolenic acid: 0.13 (-0.26, 0.52) (in mmol/L)
| Cazzola, 2007^98^ | RCT (Placebo, 1.35, 2.7, or 4.05 g EPA/day in young (18-42y) and older (53-70) males) | 155 total | No significant effects of treatment on the plasma concentrations of TC were observed. At right, net change is given (young left, older right) vs. placebo. Each row is increasing dose of EPA. | | | 0 (-0.44, 0.44) | | 0 (-0.39, 0.39)
| Cazzola, 2007^98^ | RCT (Placebo, 1.35, 2.7, or 4.05 g EPA/day in young (18-42y) and older (53-70) males) | 155 total | No significant effects of treatment on the plasma concentrations of TC were observed. At right, net change is given (young left, older right) vs. placebo. Each row is increasing dose of EPA. | | | -0.10 (-0.49, 0.29) | | 0.10 (-0.29, 0.49)
| Cazzola, 2007^98^ | RCT (Placebo, 1.35, 2.7, or 4.05 g EPA/day in young (18-42y) and older (53-70) males) | 155 total | No significant effects of treatment on the plasma concentrations of TC were observed. At right, net change is given (young left, older right) vs. placebo. Each row is increasing dose of EPA. | | | 0 (-0.39, 0.39) | | 0.20 (-0.19, 0.59)
| Rallidis, 2004^99^ | RCT (linseed oil) | 90 | Non-sig. increase in TC. | | | +10 (-9.5, 29.5)
| Lovegrove, 2004^100^ | RCT (4 g fish oil) | 84 | No change in TC (in Europeans and Indo-Asians) | | | Euro: +0.1 (-0.1, 0.3) mmol/L Indian: 0 (-0.4, 0.4)
| Lee, 2006^101^ | RCT (Omacor (a pharmaceutical capsule formulation of highly purified and concentrated n_3 PUFAs; Solvay Healthcare, Southampton, UK) 1g/day) | 77 | Non-sig decrease in TC. | | | -0.02 (-0.37, 0.33)
| Rallidis, 2003^102^ | RCT (linseed oil) | 76 | Non-sig. increase in TC. | | | +10 (-10.17, 30.17)
| Hill, 2007^103^ | RCT 2×2 Factorial (6g tuna oil, exercise) | 38 | 6g tuna oil with no exercise intervention in both groups produced non-sig. reduction in TC. | | | -0.01 (-0.77, 0.75)
| Hill, 2007^103^ | RCT 2×2 Factorial (6g tuna oil, exercise) | 37 | 6g tuna oil with exercise in both groups produced non-sig increase in TC. | | | +0.06 (-0.74, 0.86)
| Mita, 2007^104^ | RCT (1800 EPA mg/d) | 60 | Non-sig reduction in TC. | | | -0.12 (-0.58, 0.34)
| | | | | | | Net effect
LDL cholesterol 15 RCTs (14 FO, 2 ALA) (N≥60 [parallel design], N≥40 [crossover]); 9 “The effect of omega-3 fatty acid consumption was fairly uniform across studies. Most found a net increase in LDL with treatment.”; 10 “The effect of plant oils (ALA) on [LDL] was possibly weaker but similar to the effect of marine oils.”; 11 13 fish oil studies: Summary net effect +6 (95% CI +3, +8) mg/dL[3]; 12 3 ALA studies: Range of net effects -2, +3 mg/dL[4]; 13 No clear evidence of different effects in different populations; 14 Inadequate or inconsistent evidence regarding covariates, dose, source, or type of n-3 FA; 15 No difference in effect seen across 8 weeks and 2 years of exposure.; 16 No evidence on sustainment of effect. | Pan, 2009^92^ | Meta-analysis (flaxseed) | 1471 | Sig. decrease in LDL. Note: this includes lignans (0g ALA) intervention for 181 patients. | | | -0.08 (-0.16, 0.00)
| Pan, 2009^92^ | Meta-analysis (flaxseed) | Varies | Meta-regression analysis showed that sex, type of intervention (whole flaxseed, flaxseed oil, or lignan supplement (0g ALA)), study quality (Jadad score), and initial lipid concentrations influenced the net change in LDL. | | | -0.16 (-0.25, -0.06) Whole flaxseed studies
| Pan, 2009^92^ | Meta-analysis (flaxseed) | Varies | | | | +0.06 (-0.04, 0.17) Flaxseed oil studies
| Pan, 2009^92^ | Meta-analysis (flaxseed) | Varies | | | | -0.17 (-0.28, -0.06) Female studies
| Pan, 2009^92^ | Meta-analysis (flaxseed) | Varies | | | | +0.07 (-0.04, 0.18) Male studies
| Oikawa, 2009^26^ (JELIS) | RCT (EPA supplement) | 14,080 | Among those with normoglycemia, no significant effect | | | Estimated: -1 (-2.0, -0.04) [SE 0.49] -0.2 (-1.1, +0.7)
| Oikawa, 2009^26^ (JELIS) | RCT (EPA supplement) | 4565 | Among those with impaired glucose metabolism, no significant effect | | | Estimated: +1 (-0.8, +2.7) [SE 0.88] [image]
| Saitio, 2008^93^ (JELIS) | RCT (EPA supplement) | 957 | For high-risk group (TG ≥150 mg/dL and HDL-C <40 mg/dL), no sig effect on LDL. | | | Estimated: 0 (-4.13, +4.13)
| Caslake, 2008^95^ (FINGEN) 18779276 | Randomized, dose-response, cross-over (FO supplement 0.7 or 1.8 g EPA+DHA/d) | 312 | Both 0.7 and 1.8 g FO dose groups had sig. higher LDL (P=0.01), and there was no sig. dose effect. | | | Net diff cannot be estimated because the SE for all 3 groups was the same due to crossover design
| Griffin, 2006^97^ (OPTILIP) | RCT (6%of kcal from PUFAs with an n6:n3 of 10:1 (control), 5:1 when the n3 fatty acids were predominantly α-linolenic acid (18:3n3), 3:1 when the n3 fatty acids were predominantly long-chain n3 PUFAs (EPA and DHA), or both α-linolenic acid and long chain n3 PUFA) | 258 | No sig. effect on LDL | | | Estimated: n3 LC PUFA: 0.08 (-0.29, 0.45) High α-linolenic acid: -0.05 (-0.43, 0.33) N3 LC PUFA + α-linolenic acid: 0.2 (-0.19, 0.59) Moderate α-linolenic acid: 0.04 (-0.35, 0.43) (in mmol/L)
| Maki, 2010^105^ | RCT (n-3 4g/d or placebo combined with open-label simvastatin 40 mg/d) | 256 | Subgroup analysis: the baseline LDL cholesterol had a significant interaction with n-3 treatment for the LDL cholesterol response (p=0.022 for the treatment by baseline tertile interaction) | | | % change from baseline Tertile 1 (LDL <80.4 mg/dl): n-3 9.5% vs. placebo 1.1% Tertile 2 (80.4-<99.0mg/dl): n-3 -0.9% vs. placebo -3.8% Tertile 2 (≥99.0mg/dl): n-3 -6.4% vs. placebo -4.5%
| Cazzola, 2007^98^ | RCT (Placebo, 1.35, 2.7, or 4.05 g EPA/day in young (18-42y) and older (53-70) males) | 155 total | No significant effects of treatment on the plasma concentrations of LDL were observed. At right, net change is given (young left, older right) vs. placebo. Each row is increasing dose of EPA. | | | 0.30 (-0.09, 0.69) | | | -0.10 (-0.49, 0.29)
| Cazzola, 2007^98^ | RCT (Placebo, 1.35, 2.7, or 4.05 g EPA/day in young (18-42y) and older (53-70) males) | 155 total | No significant effects of treatment on the plasma concentrations of LDL were observed. At right, net change is given (young left, older right) vs. placebo. Each row is increasing dose of EPA. | | | 0.10 (-0.18, 0.38) | | | -0.10 (-0.49, 0.29)
| Cazzola, 2007^98^ | RCT (Placebo, 1.35, 2.7, or 4.05 g EPA/day in young (18-42y) and older (53-70) males) | 155 total | No significant effects of treatment on the plasma concentrations of LDL were observed. At right, net change is given (young left, older right) vs. placebo. Each row is increasing dose of EPA. | | | 0.20 (-0.19, 0.59) | | | 0.10 (-0.18, 0.38)
| Tuttle, 2008^106^ | RCT (Med. Diet (>.75% cal. omega-3 ) vs. low-fat diet in MI survivors) | 101 | Non-sig. increase in LDL. | | | +3 (-8.7, 14.7)
| Rallidis, 2004^99^ | RCT (linseed oil vs. safflower oil) | 90 | Non-sig. increase in LDL. | | | +3 (-15.9, 21.9)
| Lovegrove, 2004^100^ | RCT (4 g fish oil) | 84 | No change in LDL (in Europeans and Indo-Asians) | | | Euro: +0.1 (-0.1, 0.3) mmol/L Indian: +0.1 (-0.3, 0.5)
| Lee, 2006^101^ | RCT (Omacor (a pharmaceutical capsule formulation of highly purified and concentrated n_3 PUFAs; Solvay Healthcare, Southampton, UK) 1g/day) | 77 | Non-sig. decrease in LDL vs. control. | | | -0.05 (-0.37, 0.27)
| Rallidis, 2003^102^ | RCT (linseed oil vs. safflower oil) | 76 | Non-sig increase in LDL | | | +3 (-16.55, 22.55)
| | | | | | | Net effect
HDL cholesterol 19 RCTs (18 FO, 2 ALA) (N≥60 [parallel design], N≥40 [crossover]); 17 The studies “were heterogeneous, but mostly found small (0% to 6%), non-significant net increases in level of [HDL].”; 18 “The effect of plant oils (ALA) on [HDL] was possibly weaker but similar to the effect of marine oils.”; 19 17 fish oil studies: Summary net effect +1.6 (95% CI +0.8, +2.3) mg/dL[5]; 20 3 ALA studies: Range of net effects -1, +1 mg/dL[6]; 21 No clear evidence of different effects in different populations; 22 Inadequate or inconsistent evidence regarding covariates, dose, source, or type of n-3 FA; 23 “ No clear effect across [or within 5] studies… based on duration of intervention or exposure.”; 24 No evidence on sustainment of effect. | Pan, 2009^92^ 19515737 | Meta-analysis (flaxseed) | 1353 | Non-sig. decrease in HDL. Note: this includes lignans (0g ALA) intervention for 181 patients. | | | -0.02 (-.04, 0.00)
| Oikawa, 2009^26^ (JELIS) | RCT (EPA supplement) | 14,080 | Among those with normoglycemia, no significant effect | | | Estimated: -1 (-1.5, -0.5) [SE 0.28] -0.2 (-0.6, +0.3)
| Oikawa, 2009^26^ (JELIS) | RCT (EPA supplement) | 4565 | Among those with impaired glucose metabolism, sig lower final HDL with EPA (not clinically relevant) | | | Estimated: 0 (-0.9, +0.9) [SE 0.46] [image]
| Saitio, 2008^93^ (JELIS) | RCT (EPA supplement) | 957 | For high-risk group (TG ≥150 mg/dL and HDL-C <40 mg/dL), no sig effect on HDL. | | | Estimated: 0 (-0.99, +0.99)
| Hjerkinn, 2005^94^ | RCT: 2×2 factorial (Dietary counseling, 2.4g/d n-3 PUFA) | 281 | 2.4 g/d n-3 in treatment group with no diet intervention in both groups produced a non-sig. increase in HDL. | | | +0.07 (-0.02, 0.16)
| Hjerkinn, 2005^94^ | RCT: 2×2 factorial (Dietary counseling, 2.4g/d n-3 PUFA) | 280 | 2.4 g/d n-3 in treatment group with diet intervention in both groups produced a non-sig. increase in HDL. | | | +0.02 (-0.08, 0.12)
| Caslake, 2008^95^ (FINGEN) | Randomized, dose-response, cross-over (FO supplement 0.7 or 1.8 g EPA+DHA/d) | 312 | Both 0.7 and 1.8 g FO dose groups had sig. higher HDL (P<0.01), and there was no sig. dose effect. | | | Net diff cannot be estimated because the SE for all 3 groups was the same due to crossover design
| Grundt, 2003^96^ | RCT (FO supplement ~2g EPA+DHA/d) | 239 | EPA+DHA supplement sig. increased HDL (P<0.001) | | | Estimated: 0.13 (0.05, 0.21) mmol/L
| Griffin, 2006^97^ (OPTILIP) | RCT (6%of kcal from PUFAs with an n6:n3 of 10:1 (control), 5:1 when the n3 fatty acids were predominantly α-linolenic acid (18:3n3), 3:1 when the n3 fatty acids were predominantly long-chain n3 PUFAs (EPA and DHA), or both α-linolenic acid and long chain n3 PUFA) | 258 | No sig. effect on HDL | | | Estimated: n3 LC PUFA: 0.01 (-0.15, 0.17) High α-linolenic acid: -0.01 (-0.18, 0.16) N3 LC PUFA + α-linolenic acid: 0.03 (-0.15, 0.21) Moderate α-linolenic acid: -0.01 (-0.18, 0.16) (in mmol/L)
| Maki, 2010^105^ | RCT (n-3 4g/d or placebo combined with open-label simvastatin 40 mg/d) | 256 | Subgroup analysis: the baseline LDL cholesterol did not have a significant interaction with n-3 treatment for the HDL cholesterol. | | | % change from baseline Tertile 1 (LDL <80.4 mg/dl): n-3 4% vs. placebo -1% Tertile 2 (80.4-<99.0mg/dl): n-3 2% vs. placebo -1% Tertile 2 (≥99.0mg/dl): n-3 4% vs. placebo -1%
| Cazzola, 2007^98^ | RCT (Placebo, 1.35, 2.7, or 4.05 g EPA/day in young (18-42y) and older (53-70) males) | 155 total | No significant effects of treatment on the plasma concentrations of HDL were observed. At right, net change is given (young left, older right) vs. placebo. Each row is increasing dose of EPA. | | | -0.10 (-0.38, 0.18) | | | 0 (-0.28, 0.28)
| Cazzola, 2007^98^ | RCT (Placebo, 1.35, 2.7, or 4.05 g EPA/day in young (18-42y) and older (53-70) males) | 155 total | No significant effects of treatment on the plasma concentrations of HDL were observed. At right, net change is given (young left, older right) vs. placebo. Each row is increasing dose of EPA. | | | -0.10 (-0.38, 0.18) | | | 0.20 (-0.08, 0.48)
| Cazzola, 2007^98^ | RCT (Placebo, 1.35, 2.7, or 4.05 g EPA/day in young (18-42y) and older (53-70) males) | 155 total | No significant effects of treatment on the plasma concentrations of HDL were observed. At right, net change is given (young left, older right) vs. placebo. Each row is increasing dose of EPA. | | | 0 (-0.39, 0.39) | | | 0 (-0.28, 0.28)
| Tuttle, 2008^106^ | RCT (Med. Diet (>.75% cal. omega-3 ) vs. low-fat diet in MI survivors) | 101 | Non-sig. decrease in HDL. | | | -2 (-6.2, 2.2)
| Rallidis, 2004^99^ | RCT (linseed oil vs. safflower oil) | 90 | Non-sig. decrease in HDL. | | | -.8 (-4.8, 3.1) mg/dl
| Lovegrove, 2004^100^ | RCT (4 g fish oil) | 84 | Significant (relative) increase in HDL (in Europeans and Indo-Asians, combined, P=0.03) | | | Euro: +0.1 (-0.02, 0.2) mmol/L Indian: 0 (-0.2, 0.2)
| Lee, 2006^101^ | RCT (Omacor (a pharmaceutical capsule formulation of highly purified and concentrated n_3 PUFAs; Solvay Healthcare, Southampton, UK) 1g/day) | 77 | Non-sig. effect on HDL vs. control. | | | +0.01 (-0.11, 0.13)
| Rallidis, 2003^102^ | RCT (linseed oil vs. safflower oil) | 76 | Non-sig. decrease in HDL | | | -0.8 (-4.92, 3.32)
| Hill, 2007^103^ | RCT 2×2 Factorial (6g tuna oil, exercise) | 38 | 6g tuna oil with no exercise intervention in both groups produced non-sig. increase in HDL. | | | +0.1 (-0.23, 0.43)
| Hill, 2007^103^ | RCT 2×2 Factorial (6g tuna oil, exercise) | 37 | 6g tuna oil with exercise in both groups produced non-sig increase in HDL. | | | +0.15 (-0.16, 0.46)
| Mita, 2007^104^ | RCT (1800 EPA mg/d) | 60 | Non-sig. increase in HDL | | | +0.12 (-0.12, 0.36)
| | | | | | | Net effect
Triglycerides 19 RCTs (18 FO, 2 ALA) (N≥60 [parallel design], N≥40 [crossover]); 25 “Most of [the] studies reported a net decrease in Tg of about 10% to 33%.” “However, 1 of 2 studies of plant oils (ALA) found a net increase in TG.”; 26 17 fish oil studies: Summary net effect -27 (95% CI -33, -20) mg/dL; Higher baseline TG and higher dose associated with larger effect.[7]; 27 3 ALA studies: Range of net effects -19, +23 mg/dL[8]; 28 “The effect was… generally consistent among healthy subjects and patients with CVD, dyslipidemia, or at elevated risk of CVD.” (No study of diabetic patients had sufficient number of subjects to be analyzed.); 29 “The effect was dose-dependent… [and] greater in studies with higher mean baseline TG.”; 30 “Limited data suggest the effect is not related to sex, age, weight, background diet, or lipid treatment.”; 31 “The effect of duration of intervention is unclear.”; 32 No evidence on sustainment of effect. | Pan, 2009^92^ | Meta-analysis (flaxseed) | 1359 | Non-sig. decrease in Triglycerides. Note: this includes lignans (0g ALA) intervention for 181 patients. | | | -0.03 (-0.08, 0.02)
| Oikawa, 2009^26^ (JELIS) | RCT (EPA supplement) | 14,080 | Among those with normoglycemia, sig lower final TG with EPA (not clinically relevant) | | | Estimated from medians and IQR: -8 (-10, -6) [SE 1.2] -10 (-12, -8)
| Oikawa, 2009^26^ (JELIS) | RCT (EPA supplement) | 4565 | Among those with impaired glucose metabolism, sig lower final TG with EPA (not clinically relevant) | | | Estimated from medians and IQR: -12 (-17, -7) [SE 2.6] -10 (-12, -8)
| Saitio, 2008^93^ (JELIS) | RCT (EPA supplement) | 957 | For high-risk group (TG ≥150 mg/dL and HDL-C <40 mg/dL), sig decreased in TG | | | EPA: -23% (nd) Control: -18% (nd) P=0.012 (not included in MA)
| Hjerkinn, 2005^94^ | RCT: 2×2 factorial (Dietary counseling, 2.4g/d n-3 PUFA) | 281 | 2.4 g/d n-3 in treatment group with no diet intervention in both groups produced a non-sig. decrease in TG. | | | -0.17 (-0.38, 0.04) -10.2 (-12.2, -8.3)
| Hjerkinn, 2005^94^ | RCT: 2×2 factorial (Dietary counseling, 2.4g/d n-3 PUFA) | 280 | 2.4 g/d n-3 in treatment group with diet intervention in both groups produced a sig. decrease in TG. | | | -0.23 (-0.42, -0.04) -10.4 (-12.3, -8.4)
| Caslake, 2008^95^ (FINGEN) | Randomized, dose-response, cross-over (FO supplement 0.7 or 1.8 g EPA+DHA/d) | 312 | Both 0.7 and 1.8 g FO dose groups had sig. reduced TG (-8% and -11.2%, respectively, P<0.001), and there was no sig. dose effect. | | | Net diff cannot be estimated because the SE for all 3 groups was the same due to crossover design
| Caslake, 2008^95^ (FINGEN) | Randomized, dose-response, cross-over (FO supplement 0.7 or 1.8 g EPA+DHA/d) | 149 | In men, there was sig. dose effect on TG reduction | | | Data were not reported.
| Caslake, 2008^95^ (FINGEN) | Randomized, dose-response, cross-over (FO supplement 0.7 or 1.8 g EPA+DHA/d) | 163 | In women, there was no sig. dose effect on TG reduction | | | Data were not reported. P<0.038 for treatment × sex interaction.
| Grundt, 2003^96^ | RCT (FO supplement ~2g EPA+DHA/d) | 145 | EPA+DHA supplement sig. lowered HDL (P<0.001) | | | Estimated: -0.62 (-0.83, -0.41) mmol/L -10.9 (-12.8, -8.9)
| Griffin, 2006^97^ (OPTILIP) | RCT (6%of kcal from PUFAs with an n6:n3 of 10:1 (control), 5:1 when the n3 fatty acids were predominantly α-linolenic acid (18:3n3), 3:1 when the n3 fatty acids were predominantly long-chain n3 PUFAs (EPA and DHA), or both α-linolenic acid and long chain n3 PUFA) | 258 | No sig. effect on TG | | | Estimated: n3 LC PUFA: 0.02 (-0.19, 0.23) -10.7 (-12.7, -8.8) High α-linolenic acid: 0.01 (-0.22, 0.24) (not included in MA) N3 LC PUFA + α-linolenic acid: -0.13 (-0.34, 0.08) (not included in MA) Moderate α-linolenic acid: 0.13 (-0.10, 0.34) (in mmol/L) (not included in MA)
| Maki, 2010^105^ | RCT (n-3 4g/d or placebo combined with open-label simvastatin 40 mg/d) | 256 | Subgroup analysis: the baseline LDL cholesterol did not have a significant interaction with n-3 treatment for TG. | | | % change from baseline Tertile 1 (LDL <80.4 mg/dl): n-3 -27% vs. placebo -8% Tertile 2 (80.4-<99.0 mg/dl): n-3 -32% vs. placebo -5% Tertile 2 (≥99.0mg/dl): n-3 -30% vs. placebo -6% (not included in MA)
| Lindman, 2004^107^ | RCT (2*2 factorial designed study, corn oil 2.4g/d; corn oil 2.4g/d + dietary advice; n-3 supplements 2.4g/d; n-3 supplements 2.4g/d + dietary advice) | 219 | N-3 supplementation significantly reduced the TG levels compared to no n-3 supplementation group. | | | ß (95% CI) TG (mmol/l): -0.11 (-0.19, -0.03) (p=0.01) -10.6 (-12.5, -8.8)
| Cazzola, 2007^98^ | RCT (Placebo, 1.35, 2.7, or 4.05 g EPA/day in young (18-42y) and older (53-70) males) | 155 total | There was a sig. decrease in TG for the young groups across all dosages. Non-sig. effect for the older groups. At right, net change is given (young left, older right) vs. placebo. Each row is increasing dose of EPA. | | | | Young | | Old
| Cazzola, 2007^98^ | RCT (Placebo, 1.35, 2.7, or 4.05 g EPA/day in young (18-42y) and older (53-70) males) | 155 total | | | | Low dose | -0.40 (-0.68, -0.12) -10.8 (-12.7, -8.9) | | 0 (-0.28, 0.28) -10.7 (-12.6, -8.9)
| Cazzola, 2007^98^ | RCT (Placebo, 1.35, 2.7, or 4.05 g EPA/day in young (18-42y) and older (53-70) males) | 155 total | | | | Medium dose | -0.40 (-0.68, -0.12) -10.9 (-12.7, -9.0) | | -0.10 (-0.38, 0.18) -10.9 (-12.7, -9.0)
| Cazzola, 2007^98^ | RCT (Placebo, 1.35, 2.7, or 4.05 g EPA/day in young (18-42y) and older (53-70) males) | 155 total | | | | High dose | -0.30 (-0.58, -0.02) -10.9 (-12.8, -9.1) | | -0.10 (-0.38, 0.18) -10.9 (-12.8, -9.1)
| Tuttle, 2008^106^ | RCT (Med. Diet (>.75% cal. omega-3 ) vs. low-fat diet in MI survivors) | 101 | Non-sig. increase in TG. | | | +41 (-10.4, 92.4) -10.9 (-12.7, -9.0)
| Lovegrove, 2004^100^ | RCT (4 g fish oil) | 84 | Significant decrease in TG (in Europeans and Indo-Asians, combined, P=0.002) | | | Euro: -0.1 (-0.3, 0.1) mmol/L -10.8 (-12.7, -9.0) Indian: -0.5 (-0.9, -0.1) -10.9 (-12.7, -9.1)
| Lee, 2006^101^ | RCT (Omacor (a pharmaceutical capsule formulation of highly purified and concentrated n_3 PUFAs; Solvay Healthcare, Southampton, UK) 1g/day) | 77 | No sig. effect on TG. | | | 0 (-0.36, 0.36) -10.9 (-12.7, -9.1)
| Rallidis, 2003^102^ | RCT (linseed oil vs. safflower oil) | 76 | Non-sig. increase in TG | | | +25 (-20.89, 70.89) (not included in MA, because this study examined ALA)
| Hill, 2007^103^ 17490962 | RCT 2×2 Factorial (6g tuna oil, exercise) | 38 | 6g tuna oil with no exercise intervention in both groups produced non-sig. decrease in TG. | | | -0.21 (-0.71, 0.29) -10.9 (-12.7, -9.1)
| Hill, 2007^103^ 17490962 | RCT 2×2 Factorial (6g tuna oil, exercise) | 37 | 6g tuna oil with exercise in both groups produced non-sig decrease in TG. | | | -0.31 (-1.23, 0.61) -10.9 (-12.7, -9.1)
| Mita, 2007^104^ | RCT (1800 EPA mg/d) | 60 | Non-sig. increase in TG. | | | +0.18 (-0.30, 0.66) -10.9 (-12.7, -9.0)

* In the first column (Report findings/conclusions), the data in bold text are the meta-analyses from the report (or ancillary journal articles) that we used as the base for the “Ottawa Method.”

# In the fifth column (Data), all values are net differences (of continuous outcomes) between omega-3 fatty acid and control; the units of measurement are not included. The values and 95 percent confidence intervals (the data in parentheses) in bold text are the FEM meta-analyses with the addition of that row's study. Estimates and 95 percent confidence intervals in gray highlighting are positive signals (B1 or B2 using the Ottawa method). These are the last meta-analyses done for the respective outcome.