# Summary Tables

## Cognitive Function

Table B1 Updating effects of omega-3 fatty acids on cognitive function with aging, dementia, and neurological disease

Conclusions in 2005 Report | RAND Literature Search | Expert Opinion | Conclusion from RAND EPC | Ottawa Update Signals
Key Question 1: What is the evidence that omega-3 FA play a role in maintaining cognitive function in normal aging?
Only one study (n=818, all men) that met inclusion criteria assessed the role of omega-3 FA in maintaining cognitive function. Fish consumption was only weakly associated with a reduced risk of cognitive impairment and had no association with cognitive decline. Omega-3 FA consumption was not associated with either outcome. | The evidence base is much larger than before, and it includes RCTs and measures of plasma biomarkers that are related to omega-3 FA intake. The updated search found 13 relevant studies (4 RCTs, 9 prospective cohort studies) representing a total of n=15,739 unique subjects. Six studies showed no or weak positive associations between cognitive decline or function and omega-3 intake or related plasma biomarkers. The remaining seven studies found a positive effect of increased fish/omega-3 intake or related plasma biomarkers on cognitive function or risk of cognitive decline. Four studies showed stronger protective effects for those with low depression, hypertension, dyslipidemia, and APOE-e4 noncarrier status. One study (Van Gelder, 2007) evaluated the same population as the 1997 study included in the prior report, using a longer followup period and refined dietary intake variables. The 2007 study arrived upon different conclusions, finding a strong inverse association between no fish intake and EPA+DHA intake with cognitive decline – a relationship which was not significant in the 1997 study. | Three experts recommended additional articles, which were screened and included if they met inclusion criteria. Other than citing those studies' findings, experts did not provide detailed commentary about whether they felt the evidence had changed. One expert believed the conclusion is strengthened based on recent evidence. | The original conclusion is probably out of date and this portion of the CER may need updating based on substantial new data, including different conclusions about the same study group described in the prior report. | A4, important change in effectiveness short of opposing findings, and A6, clinically important caveat. Both signals are from a pivotal study, defined by sample size of n=7,814, but in a specialty medical journal rather than a major general journal. Three other signals met: increase in total number of trials by ≥ 50%, increase in total number of subjects by ≥ 50%, publication of new trial with n ≥ 3 times the size of the previous largest trial.
Key Question 2: What is the evidence that omega-3 FA affect the incidence of dementia including Alzheimer's disease?
Three studies (combined n=7,323) evaluated the effect of omega-3 FA on the incidence of dementia, relative to fish consumption; one study also assessed risk relative to total omega-3 FA consumption, and relative to consumption of ALA, EPA, and DHA, individually. Fish intake was associated with a significant reduction in the incidence of non-Alzheimer's dementia in one study; and a significantly reduced risk of Alzheimer's dementia in one study. Intake of total omega-3 FA and DHA alone (but not ALA or EPA alone) were associated with a significant reduction in the incidence of Alzheimer's. | The evidence base is much larger than before, and it includes measures of plasma biomarkers that are related to omega-3 FA intake. The updated search found six relevant studies (all prospective cohort studies) representing a total of n=17,275 unique subjects. Two studies found no relationship between omega-3 intake (including total and EPA or DHA alone) or related plasma biomarkers and incidence of dementia or Alzheimer's. Four studies found positive effects of these diet and plasma variables and reduced risk of developing dementia or Alzheimer's. Studies that measured APOE-e4 carrier status found mixed results about whether noncarrier status was significantly protective. One study (Devore, 2009) evaluated the same population as a 1997 study included in the prior report, using a longer follow-up period (10 years vs. 2 years). The 2007 study arrived upon different conclusions, finding no significant relationship between increased fish intake and reduced risk of dementia. | Three experts recommended additional articles, which were screened and included if they met inclusion criteria. One commented that “several clinical trials investigating the effects of omega-3-fatty acid supplementation in AD have been completed and all failed.” Another expert noted, “there are some small RCTs that suggest benefit but no definitive trial that would result in recommendations to use omega-3 to prevent or delay cognitive decline.”. | The original conclusion is probably out of date and this portion of the CER may need updating based on substantial new data, including different conclusions about the same study group described in the prior report. | A4, important change in effectiveness short of opposing findings and A6, clinically important caveat. The signals are from several non-pivotal studies, as no studies surpassed the previous largest sample size by a factor of 3. Two other signals met: increase in total number of trials by ≥ 50%, increase in total number of subjects by ≥ 50%
Key Question 3: What is the evidence that omega-3 FA are effective in the treatment of dementia including Alzheimer's disease?
Only one study (n=20) assessed the effects of omega-3 FA for the treatment of dementia. DHA resulted in a small improvement in scores on a dementia rating scale. | The evidence base is stronger than before. The updated search found 2 relevant studies (both RCTs) representing a total of n=209 unique subjects. One of these studies found a positive effect of n-3 PUFA supplementation on one measure of global cognitive function for younger subjects with cognitive impairment, but null effects for several other cognitive measures. The other study found no effect for subjects with mild to moderate Alzheimer's. | One expert commented that “evidence continues to be very weak; no substance has been shown to improve outcomes once the disease is clinically evident.” Another expert responded that “several clinical trials investigating the effects of omega-3 FA supplementation in AD have been completed and all failed to demonstrate its efficacy in the treatment of AD. However, these trials produced intriguing data suggesting that the beneficial effects of omega-3 FA supplementation may depend on the stage of disease, other dietary mediators, and APOE-e4 status.” | The original conclusion is probably out of date and this portion of the CER may need updating based on substantial new data. | A4, important changes in effectiveness short of opposing findings. This signal is from a pivotal trial defined by sample size of n=174, but in a specialty medical journal rather than a major general journal. Three other signals met: increase in total number of trials by ≥ 50%, increase in total number of subjects by ≥ 50%, publication of new trial with n ≥ 3 times the size of the previous largest trial.
Key Question 4: What is the evidence that omega-3 FA affect the incidence of OTHER neurological diseases?
Four studies (combined n=136,202) addressed the association of omega-3 FA consumption with risk or incidence of particular neurological diseases other than dementia. Two studies that assessed the association between omega-3 FA intake and the incidence of multiple sclerosis found no significant effects, although one study found a reduced risk with fish consumption in women. The one study that assessed the association between omega-3 FA consumption and the risk for Parkinson's disease found no significant association for fish, ALA, EPA, or DHA. The one study that assessed the association between maternal omega-3 FA consumption and the risk of giving birth to a child with cerebral palsy found that eating fish once a week throughout pregnancy was associated with a lower risk. | The prior evidence base was strong, and relatively little new evidence has emerged. No new studies address multiple sclerosis or cerebral palsy. The updated search found two relevant studies (one prospective cohort and one case-control study) representing a total of n=5906 unique subjects, measuring incidence of Parkinson's disease. One study found a positive, but weak/inconsistent effect of total omega-3 PUFA and ALA intake on lower incidence of Parkinson's disease, but total unsaturated fats appeared to be more important. The other study found no significant associations between intake of total omega-3 FA, ALA, EPA, or DHA and incidence of Parkinson's disease. | No relevant expert feedback. | The original conclusion is still valid and this portion of the CER does not need updating based on insufficient new data. | No qualitative signals. One other signal met: increase in total number of trials by ≥ 50%
Key Question 5: What is the evidence that omega-3 FA prevent the progression of multiple sclerosis?
Three studies (combined n=340) reported on the side effects of omega-3 FA intake on the progression of multiple sclerosis. In one study, treatment with an omega-3 FA supplement had no effect on disability or relapse rates. However, two other studies reported a significant reduction in disability and one reported improvement on an index of disease progression. | Relatively little new evidence has emerged. The updated search found one RCT study (n=27). The study found weak evidence of a positive effect of fish oil supplementation on MS quality of life and outcome measures, although treatment subjects were also subject to a lower-fat dietary intervention (vs. moderate fat in the placebo arm), which may partially explain the results. | One expert commented that 1–2 papers support the prior conclusion, but was unsure how recent those papers were relative to our original report. One expert recommended an additional systematic review, which was reference mined, but did not provide any new articles that were not already found. The expert reiterated the review's conclusions, which were that PUFAs did not have a significant effect on disease progression for MS. | The original conclusion is still valid and this portion of the CER does not need updating based on insufficient new data. | No qualitative signals. No other signals.
Are there new data that could inform the Key Questions that might not be addressed in the conclusions?
General expert responses:; #2 It seems that more detailed analyses are able to detect subgroups of patients that may be more responsive to PUFA supplementation on the basis of APOE4 status and the disease stage.; #3 Given the extensive topic areas, I would need an updated search of the literature in order to answer these questions correctly. If you have this type of search available for me to review, I would be glad to be more specific in my responses. Otherwise I do not have specific references to add and my responses at this point are that I do not know if there is evidence to invalidate the findings.; Additional Key Questions: There are new data that could inform a Key Question that is related to, but not addressed by existing Key Questions. Two new RCT studies (combined n=350) were found that evaluate the effect of omega-3 FA on treatment of Huntington Disease. One study found that ethyl-EPA supplementation did not improve motor skills for patients with HD. The other study found that MRI scans showing brain volume changes and cerebral atrophy were improved in patients treated with ethyl-EPA, noting that no other drug tested in Huntington Disease has shown this effect.

AD = Alzheimer's disease; ALA = alpha linolenic acid; CER = comparative effectiveness review; DHA = docosahexaenoic acid; EPA = eicosapentaenoic acid; FA = fatty acid; PUFA = polyunsaturated fatty acid

## Cancer Risk and Response to Treatment

Table B2 Updating effects of omega-3 fatty acids on cancer risk and response to treatment

Conclusions in 2005 Report | RAND Literature Search | Expert Opinion | Conclusion from RAND EPC | Ottawa Update Signals
Key Question 1: Effect on tumor incidence Key Question 1A: What is the evidence that omega-3 fatty acids reduce the incidence of tumors (in humans)? For what type of tumors?
All cancers, the 2005 report found that omega-3 fatty acids do not appear to decrease overall cancer risk based on finding of no effect for most types of cancer | The updated search found 2 relevant studies (2 prospective cohort studies) representing a total of n=74,701 unique participants). Both studies showed no association between intake of fish, fatty fish, DHA, or EPA and overall incidence of cancer. | These responses pertain to cancer in general as well as specific types of cancer:; #2 This conclusion is almost certainly still supported by the evidence; #4 Does not know if the conclusion is still supported by the evidence; #6 Cohort studies might provide new evidence that will change the conclusions regarding colorectal, breast, and other cancers; Engeset Eur J Cancer Prev 2009 Feb;18(1):69–75. Dietary patterns and risk of cancer of various sites in the Norwegian European Prospective Investigation into Cancer and Nutrition cohort: the Norwegian Women and Cancer study | The original conclusion is still valid and this portion of the CER does not need updating based on insufficient new data. | No signal
Aerodigestive Cancer Original report identified one study (8,006 Japanese-American men) that showed no significant effect of fish on the incidence of aerodigestive cancer (Honolulu Heart Program [Chyou 1995]) | No new studies identified | | The original conclusion is still valid and this portion of the CER does not need updating based on absence of new data. | No signal
Bladder Cancer Original report identified one study (8,006 Japanese-American men) that showed no significant effect of fish on the incidence of bladder cancer (Honolulu Heart Program [Chyou 1995]) | No new studies identified | | The original conclusion is still valid and this portion of the CER does not need updating based on absence of new data. | No signal
Breast Cancer Original report identified 7 studies (6 cohorts) Fish consumption (4 studies): 1 study found increased risk in highest vs. lowest quartile of fish intake (n=29,875 Caucasian women); other three studies found no effect (n=120,000; 14,729; 121,700) Total and marine n-3 FA (1 study): Highest quartile of marine n-3s had lower risk than women in lowest quartile (n=63,257 Asian women) Specific n-3s (1 study): Highest quartile of ALA had lower risk than lowest quartile (n=62,573 men and women[# women unknown]) No evidence for fish oil, total omega-3s, DHA, or EPA | 8 new studies (>100% increase in number of studies) with more than 50% increase in number of participants, total. Fatty fish: Contradictory findings with 1 pivotal study (by size) showing potential detrimental effect Total fish: contradictory results in two studies Total omega-3 FA: Inconsistent results, with three studies showing decreased risk and one showing no effect Marine omega-3 FA: Inconsistent results across two studies EPA: slightly decreased risk in three studies DHA: slightly decreased risk in one study ALA: Inconsistent effect on risk in one study, depending on food source Erythrocyte omega-3 FA concentrations: no effect. | #6 See Wakai Cancer Sci. 2005 Sep;96(9):590-9.; Dietary intakes of fat and fatty acids and risk of breast cancer: a prospective study in Japan Engeset D Int J Cancer 2006 Jul 1;119(1):175–182 Fish consumption and breast cancer risk. The European Prospective Investigation into Cancer and Nutrition (EPIC). Kim J BMC Cancer. 2009 Jun 30;9:216 Fatty fish and fish omega-3 fatty acid intakes decrease the breast cancer risk: a case-control study. Brasky TM. Cancer Epidemiology Biomarkers and Prevention 2010. 19(7): 1696–1708. Specialty supplements and breast cancer risk in the VITamins And Lifestyle (VITAL) cohort Gago-Dominguez M Br J Cancer 2003 Nov 3;89(9):1686–1692. Opposing effects of dietary n-3 and n-6 fatty acids on mammary carcinogenesis: The Singapore Chinese Health Study. [pre-Omega 3s-1?] | The original conclusion is still valid and this portion of the CER does not need updating based on insufficient new data. | No signal
Colorectal Cancer Original report identified 6 studies (6 cohorts): Fish consumption (4 studies): 1 study found decreased risk in highest vs. lowest quartile of fish intake in 1 study (n=14,727 women); other three studies found no effect (n=47,949 men; 3,111 men and women; 88,751 women) Total n-3 FA (1 study): Highest quartile of n-3s had non-significantly lower risk than women in lowest quartile (n=35,215 Caucasian women) Specific n-3s (1 study): No difference for any n-3 (n=61,483 Caucasian women) | eight new studies with more than 50% increase in number of participants: Total fish: inconsistent findings across four studies Marine sources of omega-3 FA: Opposing findings across three studies Total omega-3 FA: Inconsistent findings across three studies ALA: Opposing findings in men and women in one study EPA+DHA: dose dependent decrease in one study DHA: Decrease in men in one study | #5 (and #7) No clear effects of fish consumption on risk markers of colorectal cancer, confirming findings of the original report: published references:; - European J Clinical Nutrition 2009; 63(11):1353;; - Carcinogenesis 2010;31(6):1087;; - J Nutr 2010;140(2):371).; #6 Norat, J Natl Cancer Inst.2005 Jun 15;97(12):906–916.; Meat, fish, and colorectal cancer risk: the European Prospective Investigation into cancer and nutrition Kojima M Serum levels of polyunsaturated fatty acids and risk of colorectal cancer: a prospective study. (ref not included) Thiébaut AC Int J Cancer.2009 Feb 15;124(4):924–931. Dietary intakes of omega-6 and omega-3 polyunsaturated fatty acids and the risk of breast cancer. Chavarro JE Am J Clin Nutr 2008 Nov;88(5):1297–1303. A 22-y prospective study of fish intake in relation to prostate cancer incidence and mortality. Butler LM Int J Cancer 2009 Feb 1;124(3):678–686. Marine n-3 and saturated fatty acids in relation to risk of colorectal cancer in Singapore Chinese: a prospective study. Hall MN Cancer Epidemiol Biomarkers Prev 2008 May;17(5):1136–1143. A 22-year prospective study of fish, n-3 fatty acid intake, and colorectal cancer risk in men. Hall MN Cancer Epidemiol Biomarkers Prev 2007 Feb;16(2):314–321. Blood levels of long-chain polyunsaturated fatty acids, aspirin, and the risk of colorectal cancer. Daniel CR Cancer Epidemiol Biomarkers Prev 2009 Feb;18(2):516–525. Epub 2009 Feb 3. Dietary intake of omega-6 and omega-3 fatty acids and risk of colorectal cancer in a prospective cohort of U.S. men and women. | The original conclusion is still valid and this portion of the CER does not need updating based on insufficient new data. | No signal
Lung Cancer: Original report identified three studies (three cohorts) that assessed effect of n-3s on incidence and one that assessed effect on mortality One study found decreased risk with highest vs. lowest tertile fish intake; other studies found no effect of higher fish consumption on incidence or death | No new findings | | The original conclusion is still valid and this portion of the CER does not need updating based on insufficient new data. | No signal
Lymphoma: Original report identified 2 studies (2 cohorts) on incidence of non-Hodgkins lymphoma (NHL) Fish intake:1 study found no effect of increasing fish consumption (35,156 women) Total n-3s: 1 study found no effect of increasing intake of omega-3s (as % total caloric intake) (88,410 women) | 1 new case-control study (614 cases) reported significant effect of total and marine omega-3 FA on incidence of NHL | | The original conclusion is probably out of date and this portion of the CER may need updating based on new data from one large observational study | No signal
Ovarian Cancer Original report identified one study that assessed the effect of various kinds of fat, including n-3s, on incidence and found no effect | No new studies | | The original conclusion is still valid and this portion of the CER does not need updating based on insufficient new data. | No signal
Pancreatic Cancer Original report identified 2 studies (2 cohorts) Fish consumption (1 study): no significant effect of fish consumption (27,111 men) Total n-3 consumption (1 study): no effect of n-3s ALA (2 studies): no effect of ALA (27,111 men; 88,802 women) | No new studies | | The original conclusion is still valid and this portion of the CER does not need updating based on insufficient new data. | No signal
Prostate Cancer Original report identified 7 studies (5 cohorts) Fish consumption (4 studies): 1 study showed inverse effect (6,272 men); one study showed positive effect (14,000 Seventh-day Adventists); other two studies (total 56,763) showed no effect Marine omega-3s (1 study): no effect found (47,855 health professionals) DHA and EPA (two studies): no effects seen (approx. 108,000) ALA (3 studies): increased risk for advanced cancer but not overall (47,866) in one study; no significant effect in the other (58,279) (data missing for 3^rd^) | 9 new studies (7 cohorts) and MA. Total fish: findings inconsistent across 3 studies Fatty fish: no effect in 1 study Marine omega-3 FA (from fatty fish): decreased risk in 1 study Total omega-3 FA: trend toward ↓ risk in Caucasian and Latino men but no effect in others in 1 study ALA: MA showed inconsistent findings among 16 studies; inconsistent findings across 4 other studies EPA: inconsistent findings across 3 studies DHA: inconsistent findings across 2 studies Findings remain contradictory with some showing positive, some negative, and some no association | #6 See: Pham TM. Public Health Nutr 2009 May;12(5):609–613. Epub 2008 Jul 29.; Fish intake and the risk of fatal prostate cancer: findings from a cohort study in Japan. Leitzmann 2004 Dietary intake of n-3 and n-6 fatty acids and the risk of prostate cancer. Am J Clin Nutr 2004; 80(1):204–216 [in original report] | The original conclusion is still valid and this portion of the CER does not need updating based on insufficient new data. | No signal
Renal Cancer No studies in original report | Two new studies, one in a pivotal journal Baltic herring: ↑risk but nonrepresentative population (Alpha-Tocopherol Beta-Carotene Cancer (ATBC) Prevention Study of smokers Cohort study in pivotal journal: Fatty fish: ↓↓ risk Lean and other fish: no effect seen | | The original conclusion is probably out of date and this portion of the CER may need updating based on new data from one large observational study in pivotal journal | A4: One pivotal study showed strong benefit A6: One large trial showed evidence of potential harm for smokers
Skin Cancer Original report found 1 study that looked only at basal cell carcinoma (BCC). Highest n-3 consumption associated with small but significantly increased risk of BCC relative to lowest quartile. (43,217 health professionals) | 1 new study on actinic keratosis Fatty fish: ↓risk for appearance of actinic keratoses compared with lower intakes | | The original conclusion is probably out of date and this portion of the CER may need updating based on new data from one large observational study | No signal
Stomach Cancer Original report identified one study that assessed risk relative to fish consumption and found no effect. | No new studies | | The original conclusion is still valid and this portion of the CER does not need updating based on insufficient new data. | No signal
Effect on Tumor Incidence Key Question 1b: If omega-3 fatty acids influence the incidence of tumors, is there an inverse relationship with intake?
Data were insufficient to permit assessment of a dose-response relationship. Original report identified the following dose effects Breast cancer: dose effects for marine n-3s and ALA; no dose effects for fish, total n-3s, DHA, EPA Colorectal cancer: dose effects tested but not observed Lung cancer: study that reported reduced risk of CA reported dose effect Lymphoma: dose effects tested but not observed Ovarian cancer: no dose effects observed Pancreatic cancer: dose effects tested but not observed Prostate cancer: Dose effects tested in all seven studies. Dose effects seen for fish in two of four studies, but in opposite directions. Dose effects seen for ALA in two studies but in opposite directions. No dose effect seen for EPA, DHA, total n-3s Skin cancer: Study found increased risk with increasing dose Stomach cancer: dose response assessed but not seen | Two new case-control studies showed a dose-response relationship: one showed a relationship for EPA, DHA, EPA+DHA and ALA with colorectal cancer; the other showed a weak relationship for total omega-3 FA and colorectal cancer | #2 This conclusion is almost certainly still supported by the evidence; #4 Does not know if the conclusion is still supported by the evidence; #6 See articles cited for KQ1a if positive relationship found | The original conclusion is still valid and this portion of the CER does not need updating based on insufficient new data. | No signal
Effect on Tumor Incidence Key Question 1c: Is there a temporal relationship with intake?
Data were insufficient to permit assessment of a temporal relationship | No new studies were identified that addressed this question. | #4 Does not know if the conclusion is still supported by the evidence; #6 See articles cited for KQ1a if positive relationship found | The original conclusion is still valid and this portion of the CER does not need updating based on insufficient new data. | No signal
Key Question 1d: If omega-3 fatty acids influence the incidence of tumors, what is the evidence that genes involved in omega-3 fatty acid transport or metabolism influence the magnitude or direction of the influence on tumor incidence?
No studies were identified that investigated the role of omega-3 fatty acid transport or metabolism genes in any putative effect of omega-3 fatty acids on tumor incidence | One new study found a significant interaction with small nuclear polymorphism (SNP) in COX-2 gene (key enzyme in eicosanoid synthesis, over-expressed in prostate cancer tissue) but not with four other SNPs | #2 This conclusion is almost certainly still supported by the evidence; #4 Does not know if the conclusion is still supported by the evidence; #6 Does not believe there is any change in the evidence | The original conclusion is still valid and this portion of the CER does not need updating based on insufficient new data. | No signal
Key Question 1e: What is the evidence that the response to omega-3 fatty acids is independent of the intake of antioxidants such as vitamin E or other bioactive food components?
No studies were identified that allowed this question to be answered | No new studies were identified that answered this question | #2 This conclusion is almost certainly still supported by the evidence; #4 Does not know if the conclusion is still supported by the evidence; #6 Does not believe there is any change in the evidence | The original conclusion is still valid and this portion of the CER does not need updating based on insufficient new data. | No signal
Key Question 1f: What is the evidence that the response is modified by the state of the immune system?
No studies were identified that examined the possible modification of the effect of omega-3 fatty acids by immune status. | No new studies were identified that answered this question | #2 This conclusion is almost certainly still supported by the evidence; #4 Does not know if the conclusion is still supported by the evidence | The original conclusion is still valid and this portion of the CER does not need updating based on insufficient new data. | No signal
Key Question 2: Effects on Clinical Outcomes after Cancer Treatment Key Question 2a: What is the evidence that omega-3 fatty acids alter the effects of cancer treatment on malignant tumors and clinical outcomes after cancer treatments?
We identified 19 studies from which the effect of omega-3 fatty acids on clinical outcomes after cancer therapy could be ascertained, all of which pertained to patients who had undergone cancer surgery for upper gastrointestinal malignancies. We did not identify any studies that assessed the effects of omega-3 fatty acids on clinical outcomes after chemotherapy or radiation surgery. Among the identified studies, 14 described the effect on post-operative complications, 13 on hospital length of stay, 10 on mortality, 11 on nutrition and three on weight. In pooled analyses, omega-3 fatty acids had no effect compared to placebo on post-operative complications, hospital length of stay, or mortality. With the exception of one study that demonstrated higher mean nitrogen intake for subjects treated with omega-3 fatty acids relative to placebo, no significant effect on nutrition or weight loss was observed. | 2 new Phase II trials assessed response to chemotherapy: both identified improved outcomes (1 for DHA and 1 for EPA) but recommended RCTs 10 new studies assessed the response to surgery: Postoperative complication rate: Enteral formula supplemented with EPA, DHA+EPA, omega-3 FA+arg, high ratio omega-3 FA to omega-6 FA: no effect found Fish oil: inconsistent effects across 2 studies Impact enteral nutrition formula: Decreased post-op complications Length of stay: Fish oil: inconsistent effects across 2 studies Impact: 2 studies found decrease Weight gain/loss: inconsistent effects across 3 studies Nutritional parameters: inconsistent effects across 4 studies | #2 The substantial literature on Impact and other immune-enhancing diets which contain fish oil along with other immune-enhancing compounds which on meta-analysis has shown benefits for length of stay and infections in postoperative patients; #4 Does not know if the conclusion is still supported by the evidence.; #6 The following studies should be added:; - Bougnoux P Br J Cancer 2009 Dec 15;101(12):1978–1985. Epub 2009 Nov 17.; Improving outcome of chemotherapy of metastatic breast cancer by docosahexaenoic acid: a phase II trial.; Liang B World J Gastroenterol 2008 Apr 21;14(15):2434–2439. Impact of postoperative omega-3 fatty acid-supplemented parenteral nutrition on clinical outcomes and immunomodulations in colorectal cancer patients. | Chemotherapy: The original conclusion is definitely out of date and this portion of the CER needs updating based on new data from 2 Phase II trials. Postoperative recovery: The original conclusion is still valid and this portion of the CER does not need updating based on insufficient new data. | Chemotherapy: No signal Postoperative recovery, length of hospital stay, and nutritional status: No quantitative or qualitative signal
Key Question 2b: What is the evidence that the response to omega-3 fatty acids is independent of the intake of antioxidants such as vitamin E or other bioactive food components?
No studies were identified that allowed this question to be answered. | No studies were identified that allowed this question to be answered. | #2 This conclusion is almost certainly still supported by the evidence; #4 Does not know if the conclusion is still supported by the evidence | The original conclusion is still valid and this portion of the CER does not need updating based on insufficient new data. | No signal
Key Question 2c: What is the evidence that the response is modified by the state of the immune system?
No studies were identified that examined the possible modification of the effect of omega-3 fatty acids on clinical outcomes by immune status. | No studies were identified that allowed this question to be answered. | #2 This conclusion is almost certainly still supported by the evidence; #4 Does not know if the conclusion is still supported by the evidence | The original conclusion is still valid and this portion of the CER does not need updating based on insufficient new data. | No signal
Are there new data that could inform the Key Questions that might not be addressed in the conclusions?
| | #1 There is no new evidence that would alter the conclusions or require re-review.; #3 Given the extensive topic areas, I would need an updated search of the literature in order to answer these questions correctly. If you have this type of search available for me to review, I would be glad to be more specific in my responses. Otherwise I do not have specific references to add and my responses at this point are that I do not know if there is evidence to invalidate the findings.

ALA = alpha linolenic acid; arg = arginine; BCC = basal cell carcinoma, CER = comparative effectiveness review; DHA = docosahexaenoic acid; EPA = eicosapentaenoic acid; FA = fatty acid; n-3 = omega-3; PUFA = polyunsaturated fatty acid

## Cardiovascular Disease Risk Factors

Table B3 Updating effects of omega-3 fatty acids on cardiovascular disease risk factors

Conclusions in 2004 Report | Updated Literature Search and Articles From Experts | Expert Opinion | Conclusions from EPC | Ottawa Update Signals
Original Key Questions (abbreviated and re-phrased)
What is the effect of omega-3 fatty acids (EPA, DHA, ALA; fish; supplements or dietary) on cardiovascular risk factors and intermediate markers of cardiovascular disease (see list of outcomes below)? How do the effects differ by; - Dose; - Duration of intake; - Specific omega-3 fatty acid (or their ratios); - Source (e.g., dietary fish, dietary oils, dietary plants, fish oil supplement, flax seed supplement); - Ratio of omega-6 to omega-3 fatty acids; - Population (men, pre-menopausal women, post-menopausal women, different age groups); - Baseline dietary intake of omega-3 fatty acids; - Presence of potential confounders; ◦ Body mass index; ◦ Blood pressure; ◦ Medications; - Pre-existing conditions; ◦ Diabetes; ◦ Hypertension; ◦ Hyperlipidemia; ◦ Known cardiovascular disease; Are the effects sustained after the intervention or exposure stops?
Total cholesterol (TC)
23 RCTs (20 FO, 4 ALA) (N≥60 [parallel design], N≥40 [crossover]); 1. The studies “were heterogeneous, but mostly found small (0% to 6%), non-significant net increases in level of [total cholesterol].”; 2. “The effect of plant oils (ALA) on [TC] was possibly weaker but similar to the effect of marine oils.”; 3. 19 fish oil (FO) studies: Summary net effect 0 (95% CI -1, +2) mg/dL [μ=0.4257; SE=0.9537]; Higher mean baseline TC associated with larger net decrease in TC.24; 4. 5 ALA studies: Range of net effects -1, +13 mg/dL24; 5. No clear evidence of different effects in different populations; 6. Inadequate or inconsistent evidence regarding covariates, dose, source, or type of n-3 FA; 7. No difference in effect seen across 5 weeks and 2 years of exposure.; 8. No evidence on sustainment of effect. | From our literature search: 12 RCTs (9 FO, 1 n-3 FA rich diet, 2 ALA) From experts: 3 RCTs (3 FO); 1 1 RCT from literature search and 2 RCTs from experts found a significant net decrease in TC, but other studies showed no significant effect.; 2 No new data were found.; 3 9 fish oil studies from search: no sig. effect on TC in 8 studies; 3 fish oil studies from experts: no sig. effect in 1 study; 1 n-3 FA rich diet (from literature search): no sig. effect on TC; 4 2 ALA studies (from literature search): no sig. effect; 5 1 fish oil study; - No difference with normoglycemia or impaired glucose metabolism; - For high-risk group (TG ≥150 mg/dL and HDL-C <40 mg/dL), no sig effect on TC.; 6 2 fish oil studies, no clear evidence of a dose effect; 7-8 No new data were found. | Five of the six experts stated that the findings of the original report are almost or certainly still supported by the evidence; one was undecided. | - FO: Possibly out of date (based on new trials); - ALA: Possibly out of date (based on new trials) | Quantitative: FO: Change in statistical significance, NS to Sig (B1) ALA: N/A Qualitative: FO: Opposing findings (A1) ALA: Opposing findings (A1)
LDL cholesterol
15 RCTs (14 FO, 2 ALA) (N≥60 [parallel design], N≥40 [crossover]); 9 “The effect of omega-3 fatty acid consumption was fairly uniform across studies. Most found a net increase in LDL with treatment.”; 10 “The effect of plant oils (ALA) on [LDL] was possibly weaker but similar to the effect of marine oils.”; 11 13 fish oil studies: Summary net effect +6 (95% CI +3, +8) mg/dL24; 12 3 ALA studies: Range of net effects -2, +3 mg/dL24; 13 No clear evidence of different effects in different populations; 14 Inadequate or inconsistent evidence regarding covariates, dose, source, or type of n-3 FA; 15 No difference in effect seen across 8 weeks and 2 years of exposure.; 16 No evidence on sustainment of effect. | From update literature search: 10 RCTs (6 FO, 2 n-3 FA rich diet, 2 ALA) From experts: 3 RCTs (3 FO); 9 Most of the studies showed no significant effects on LDL.; 10 No new data were found.; 11 6 fish oil studies (from literature search): sig effect in 1 study; 3 fish oil studies (from experts): sig increase in 1 study; 2 n-3 FA rich diet (from literature search): no sig. effect; 12 2 ALA studies: no sig. effect; 13 2 fish oil studies; - 1 study: No difference with normoglycemia, impaired glucose, or hypertriglyceridemia; - 1 study: The baseline LDL cholesterol had a significant interaction with n-3 treatment for the LDL cholesterol response (p=0.022).; 14 2 fish oil studies, no clear evidence of a dose effect; 15-16 No new data | Five of the six experts stated that the findings of the original report are almost or certainly still supported by the evidence; one was undecided. One agreed, adding, “The question has come up as to whether there may be differences in LDL between EPA and DHA, such that EPA lowers LDL whereas DHA raises LDL. I have not seen published data in this regard but it may be worth assessing.” One also agreed but added the caveat, “All [of the original findings] relate to pharmaceutical doses of ω3, not ‘ω3 FA consumption,’ which implies diet. Minimal effect of pharma doses when given with statins.” | - FO: Overall still valid, but possible differences in different population (based on 1 large new trial); - ALA: Possibly out of date (based on new trials) | Quantitative: FO: Change in statistical significance, Sig to SNS (B1) ALA:N/A Qualitative: FO: Opposing findings (A1) ALA: Opposing findings (A1)
HDL cholesterol
19 RCTs (18 FO, 2 ALA) (N≥60 [parallel design], N≥40 [crossover]); 17 The studies “were heterogeneous, but mostly found small (0% to 6%), non-significant net increases in level of [HDL].”; 18 “The effect of plant oils (ALA) on [HDL] was possibly weaker but similar to the effect of marine oils.”; 19 17 fish oil studies: Summary net effect +1.6 (95% CI +0.8, +2.3) mg/dL24; 20 2 ALA studies: Range of net effects -1, +1 mg/dL24; 21 No clear evidence of different effects in different populations; 22 Inadequate or inconsistent evidence regarding covariates, dose, source, or type of n-3 FA; 23 “No clear effect across [or within 5] studies… based on duration of intervention or exposure.”; 24 No evidence on sustainment of effect. | From literature search: 14 RCTs (10 FO, 2 n-3 FA rich diet, 2 ALA) From experts: 3 RCTs (3 FO); 17 Most of the studies showed no significant effects on HDL.; 18 2 ALA studies (from literature search): no sig. effect; 19 10 fish oil studies (from literature search): FO groups had sig. higher HDL in 3 studies; 3 fish oil studies (from experts): FO groups had sig. higher HDL in 2 studies; 2 n-3 FA rich diet studies (from literature search): no sig. effect; 20 2 ALA studies (from literature search): no sig. effect; 21 3 fish oil studies:; - 1 study: Among those with normoglycemia or high-risk group (TG ≥150 mg/dL and HDL-C <40 mg/dL), no sig effect on HDL; Among those with impaired glucose metabolism, sig lower final HDL; - 2 studies: No different effects by the baseline LDL cholesterol or ethnicity; 22 2 fish oil studies, no clear evidence of a dose effect; 23-24 No new data were found. | Four of five experts (one omitted the question) stated that the findings of the original report are almost or certainly still supported by the evidence; one stated that they are not. One stated that the previous findings are no longer supported, adding “There seems to be now a significant increase in HDL cholesterol.” One omitted the question, but added, “Were the review to be updated an additional relevant question is whether the changes in HDL-C are dependent on the change in TG. Particularly important to split the studies on the basis of baseline TG…” One agreed the findings were still supported, adding the same caveats as he did above (LDL). | - FO: Overall still valid, but possible differences in different population (based on 1 large new trial and 2 medium size trials); - ALA: Still valid | Quantitative: FO: Change in statistical significance, Sig to SNS (B1) ALA: N/A Qualitative: FO: Opposing findings (A1) ALA: No signal
Triglycerides
19 RCTs (18 FO, 2 ALA) (N≥60 [parallel design], N≥40 [crossover]); 25 “Most of [the] studies reported a net decrease in Tg of about 10% to 33%.” “However, 1 of 2 studies of plant oils (ALA) found a net increase in Tg.”; 26 17 fish oil studies: Summary net effect -27 (95% CI -33, -20) mg/dL; Higher baseline Tg and higher dose associated with larger effect‥24; 27 3 ALA studies: Range of net effects -19, +23 mg/dL24; 28 “The effect was… generally consistent among healthy subjects and patients with CVD, dyslipidemia, or at elevated risk of CVD.” (No study of diabetic patients had sufficient number of subjects to be analyzed.); 29 “The effect was dose-dependent… [and] greater in studies with higher mean baseline Tg.”; 30 “Limited data suggest the effect is not related to sex, age, weight, background diet, or lipid treatment.”; 31 “The effect of duration of intervention is unclear.”; 32 No evidence on sustainment of effect. | From literature search: 14 RCTs (11 FO, 2 n-3 FA rich diet, 1 ALA) From experts: 4 RCTs (4 FO) 10 of 18 studies found a sig. net decrease in TG, but other studies showed no sig. effects on TG.; - 11 fish oil studies (from literature search): sig. decrease in Tg in FO group in 6 studies. In 1 study, sig decrease when FO was given in diet but not without diet; - 4 fish oil studies (from experts): sig decrease in Tg in 2 studies; - 2 n-3 FA rich diet studies (from literature search): no sig. effect; - 1 ALA study (from literature search): No sig. effect; - 1 FO study: No difference with normoglycemia, impaired glucose metabolism, or high-risk group (TG ≥150 mg/dL and HDL-C <40 mg/dL); - 2 FO studies: 1 study, sig. dose effect on TG for men, but not for women; 1 study, sig. dose effect on TG for young groups, but not for older groups; - 1 FO study: No different effects by the baseline LDL cholesterol; 31-32 No new data | Five of the six experts stated that the findings of the original report are almost or certainly still supported by the evidence; one was undecided. One agreed the findings were still supported, adding, “all outcomes could be updated for ω3 in combination with statins.” | - FO: Still valid; - ALA: Still valid | Quantitative: FO: No signal ALA: N/A Qualitative: FO: No signal ALA: No signal
Lipoprotein (a) [Lp(a)]
14 RCTs (13 FO, 1 ALA) (N≥5); 33 “No consistent effect on Lp(a) levels…. In approximately one-third of the studies the n-3 FA study arms had a net increase in Lp(a) level compared to control; in the remaining studies the net decrease in Lp(a) was generally small and non-significant.”; 34 No clear evidence of different effects in different populations; 35 Evidence (in 2 studies directly, or across studies) of no different effects based on dose or based on exposure duration; 36 Inadequate evidence regarding covariates, source or type of n-3 FA.; 37 No evidence on sustainment of effect. | From our literature search: 6 RCTs (3FO, 3 n-3 FA rich diet) From experts: 1 RCT (1ALA); 33 3 fish oil studies (from the literature search):; - 2 studies: No sig. effect on Lp(a); - 1 study: Significantly different between two groups, DHA vs. control; 3 n-3 FA rich diet (from the literature search):; - 2 studies: No sig. effect on Lp(a); 1 ALA study (from experts): No sig. effect on Lp(a); 34 No new data were found.; 35 1 fish oil study: No sig. dose effect; 36 No new data were found.; 37 No new data were found. | 3 of 6 experts stated that the findings of the original report are almost or certainly still supported by the evidence; one was undecided, one omitted the question, and one recommended not updating this outcome. | - FO: Still valid; - ALA: Still valid | Quantitative: FO: N/A ALA: N/A Qualitative: FO: No signal ALA: No signal
Apolipoprotein A-1 (apo A-1)
27 RCTs (27 FO, 2 ALA) (N≥20 [parallel design], N≥15 [crossover]); 38 The studies “generally found no effect or either a small increase or decrease in level with n-3 FA consumption.”; 39 “Limited evidence suggested that purified EPA may decrease apo A-1 levels while DHA has no effect, and that there is no difference in effect between fish oils and ALA.”; 40 No evidence of a dose effect or of different effects in different populations; 41 One study reported no association in effect with sex, BMI, hypertension, and NIDDM.; 42 Evidence (in 2 studies directly, or across studies) of no different effects based on exposure duration.; 43 Three studies followed subjects after stopping the intervention. One found a persistent decrease in apo A-1 at 5 months, but the other two studies found no difference (from baseline) after 8 weeks and 6 months. | From our literature search: 6 RCTs (4 FO, 2 n-3 FA rich diet (1 of which had FO and ALA rich diets)) From experts: 3 RCTs (2 FO, 1 ALA); 38 6 fish oil studies (from the literature search and experts): No sig. effect on apo-A1; 1 ALA study (experts): A significant net decrease in change of apo-A1; 39 2 n-3 FA rich diet: No sig. effect on apo-A1. No effect of ALA; 40 2 n-3 FA rich diet: not significantly different between 2 groups (EPA/DHA vs. ALA rich diet); 41 1 fish oil study: No sig. dose effect; 42 No new data were found.; 43 No new data were found. | 3 of 6 experts stated that the findings of the original report are almost or certainly still supported by the evidence; one was undecided, one omitted the question, and one recommended not updating this outcome. One agreed that the findings were still supported, citing one study in which the “use of flaxseed increased apolipoprotein A-1 compared to placebo.” One recommended not updating this outcome, adding, “However, were the variable retained the important question would be are the changes (or lack thereof) in apoA-1 similar to HDL….” | - FO: Still valid; - ALA: Possibly out of date (based on new trials) | Quantitative: FO: N/A ALA: N/A Qualitative: FO: No signal ALA: No signal
Apolipoprotein B (apo B)
25 RCTs (24 FO, 2 ALA) (N≥20 [parallel design], N≥10 [crossover]); 44 “Little consistency in the effect of n-3 FA on apo B levels. About half… found a small net increase and half a small net decrease.”; 45 In contrasts to studies of other populations, the 4 studies of people with diabetes all found “small, non-significant net increases in apo B.”; 46 One study found a significantly greater rise in apo B level in younger, compared to older, participants. A different study found no difference related to intake of saturated fats.; 47 Two of three studies found larger net decreases in apo B with higher doses of fish oil or dietary fish intake, but this effect was not confirmed across studies. There was no consistent evidence regarding differences among different sources of fish oils.; 48 Inadequate evidence regarding effect of exposure duration.; 49 In 3 studies, no clear evidence of any sustainment of effect. | From our literature search: 9 RCTs (6FO, 3 EPA/DHA/ALA rich diet) From experts: 4 RCTs (3 FO, 1 ALA); 44 7 fish oil studies (6 from the literature search and 1 from experts); - 7 fish oil studies: No sig. effect on apo B 2 fish oil studies (from experts): Sig. decrease in change of apo B; - 1 ALA study (from experts): No sig. effect on apo B; 3 n-3 FA/ALA rich diet:; - 2 studies: No sig. effect on apo B; - 1 study: ALA rich vs. control, ALA group had sig. lower apo B; n-3 FA rich vs. control, n-3 FA group had sig. higher apo B.; 45 1 fish oil study: No sig. effect on apo B (in Europeans and Indo-Asians); 46 No new data were found.; 47 1 fish oil study: No sig. dose effect; 48 No new data were found.; 49 No new data were found. | 3 of 6 experts stated that the findings of the original report are almost or certainly still supported by the evidence; one was undecided, one omitted the question, and one recommended not updating this outcome. One recommended not updating this outcome, adding the same caveat as above (apo A-1) but for apo B and LDL. | - FO: Still valid; - ALA: Possibly out of date (based on new trials) | Quantitative: FO: N/A ALA: N/A Qualitative: FO: No signal ALA: No signal
Apolipoprotein B-100 (apo B-100)
4 RCTs (4 FO, 0 ALA) (N≥5); 50 No consistent effect.; 51 Insufficient data to evaluate differences across populations.; 52 One study found no correlation between change in apo B-100 and sex, BMI, hypertension, or diabetes.; 53 Inadequate evidence regarding different effects based on source or dose.; 54 Possible evidence of no difference in effect based on exposure duration; 55 No evidence on sustainment of effect. | No new data were found. | One expert stated that the findings of the original report are almost or certainly still supported by the evidence; two were undecided, one recommended not updating this outcome, and two omitted the question. Two of the experts omitted the question, but both added that this should be included as part of the apo B category. | - FO: Still valid; - ALA: Still valid | Quantitative: FO: N/A ALA: N/A Qualitative: FO: No signal ALA: No signal
LDL Apolipoprotein B (LDL apo B)
6 RCTs (6 FO, 0 ALA) (N≥5); 56 Evidence suggests “large, [statistically] significant net increases in LDL apo B [of] 20-45 mg/dL.”; 57 Insufficient data to evaluate differences across populations.; 58 One study found no correlation between change in LDL apo B and diet or body weight.; 59 Inadequate evidence regarding different effects based on source or dose.; 60 Possible evidence of no difference in effect based on exposure duration; 61 No evidence on sustainment of effect. | No new data were found. | Two of the experts stated that the findings of the original report are almost or certainly still supported by the evidence; one was undecided, one recommended not updating this outcome, and two omitted the question. One omitted the question, but added that this outcome should certainly be dropped. | - FO: Still valid; - ALA: Still valid | Quantitative: FO: N/A ALA: N/A Qualitative: FO: No signal ALA: No signal
Blood pressure
Pre-existing SR in people without DM (36 RCTs, all FO) 6 RCTs (6 FO, 0 ALA) (DM, N≥15 [parallel design], N≥10 [crossover]) SR in non-diabetics:; 62 Summary net change SBP -2.1 (-3.2, -1.0) mm Hg, DBP -1.6 (-2.2, -1.0) mm Hg.; 63 SBP and DBP reductions were significantly larger in studies with mean ages ≥45 y, mean BP ≥140/90. No association with mean BMI, trial duration, or fish oil dose. Unable to assess sex.; RCTs of diabetics:; 64 “Generally small, non-significant effects on SBP and DBP”, similar to meta-analysis of studies of non-diabetics; 65 1 study found no association between sex or Hb A1c and BP effect. No consistent differences across studies based on covariates.; 66 Across studies no clear evidence of different effects based on dose, source, or duration of exposure to FO.; 67 No evidence on sustainment of effect. | 15 RCTs (12FO, 1 ALA, 1 EPA/DHA, 1 ALA rich diet); 62-63 NA; 64 12 fish oil studies:; - 10 studies: No sig. effect on SBP and DBP; - 1 study: FO group, sig. decrease in SBP, DBP; - 1 study: FO group, sig. decrease in DBP, but not in SBP; 1 ALA study (nondiabetics): ALA group, sig. decrease in SBP, DBP; 1 EPA/DHA rich diet: No sig. effect on SBP, DBP; 1 ALA rich diet (type 2 DM): Walnut-enriched vs. control diet, sig. increase in SBP, DBP; 65 1 study showed that the results were similar after adjusting for age, race, gender, and baseline DBP or SBP.; 66 No new data were found.; 67 No new data were found. | Four of the experts stated that the findings of the original report are almost or certainly still supported by the evidence; one stated that they are not, and one was undecided. | - FO: Possibly out of date (mostly based on minority expert opinion); - ALA: Probably out of date (based on trials) | Quantitative: FO (no DM): SBP: Change in statistical significance, Sig to NS (B1) DBP: Change in effect size of at least 50%, Sig -2 to Sig +0.4 mm Hg (B2) FO (w/DM): N/A ALA: N/A Qualitative: FO (no DM): SBP: Opposing findings (A1) DBP: Opposing findings (A1) FO (w/DM): No signal ALA: No signal (or A4, new trials where there were none)
Hemoglobin A1c
18 RCTs (18 FO, 0 ALA) (N≥10); 68 “n-3 FA had a very small, if any, effect on Hgb A1c levels compared to control.”; 69 Summary net effect 0.1% (95% CI -0.01, +0.2) ; Homogeneous24; 70 No clear difference across studies based on sub-populations; 71 1 study found no correlation in effect with diet or body weight. Another study found no difference between men and women.; 72 2 studies found no difference in effect based on dose. Also no evidence of a dose effect across studies.; 73 2 studies found no overall difference in effect at different time points.; 74 1 study found that Hgb A1c remained unchanged 8 weeks after stopping supplementation. | 5 RCTs (4FO, 1 ALA rich diet); 68-69 4 fish oil studies: No sig. effect on Hemoglobin A1c; - ALA rich diet: No sig. effect on Hemoglobin A1c; 70 2 fish oil studies: No sig. difference across studies based on sub-populations; 71-74 No new data were found. | Four of the experts stated that the findings of the original report are almost or certainly still supported by the evidence; two were undecided. | - FO: Still valid; - ALA: Probably out of date (based on 1 new trial) | Quantitative: FO: No signal ALA: N/A Qualitative: FO: No signal ALA: No signal (or A4, new trial where there were none)
Fasting glucose
17 RCTs (18 FO, 0 ALA) (N≥25 [parallel design], N≥15 [crossover]); 75 “The effect of n-3 FA on [fasting glucose] was inconsistent across the studies.”; 76 Summary net effect 3.0 (95% CI -0.2, +6) mg/dL; Higher mean baseline fasting glucose and higher dose associated with larger net increases in fasting glucose.24; 77 No clear difference across studies based on sub-populations; 78 3 studies found no correlations in effect with diet or body weight.; 79 No evidence within or across studies suggesting differences based on source or dose (based on qualitative analysis).; 80 2 studies found no overall difference in effect at different time points.; 81 2 studies found that any changes in fasting glucose reverted to baseline after 8 or 12 weeks after stopping supplementation. | From update searcH: 12 RCTs (1 EPA, 1 FO vs EPA+DHA, 1 n-3 FA+ALA,1 Mediterranean diet, 3 n-3 FA, 1 fish oil, 1 EPA+DHA, 1 DHA, 1 walnut,) were identified. From experts: 2 RCTs (1 fish oil, fatty fish, lean fish diet vs. no fish control diet; 1 flaxseed vs. wheat germ); 75-76 One RCT that compared fish oil and corn oil reported sig. higher fasting glucose and lower glucose utilization in fish oil group compared with corn oil group. Another RCT sent from expert showed that subjects who consumed fish oil and fish diets had (median) decreases in fasting glucose, while control subjects did not (no statistical testing was done). All other RCTs (fish oil, n-3 rich diets or ALA) reported no sig. difference between groups, including the 1 ALA study sent from expert.; 77-81 no new data were found. | Four of the experts stated that the findings of the original report are almost or certainly still supported by the evidence; two stated that they are not. | - FO: Possibly out of date (based on minority expert opinion); - ALA: Probably out of date (based on new trials) | Quantitative: FO: Change in significance, NS to Sig (B1) ALA: N/A Qualitative: FO: No signal^a^ ALA: No signal (or A4, new trials where there were none)
Fasting insulin
15 RCTs (18 FO, 0 ALA) (N≥5); 82 Baseline fasting insulin levels varied widely within and between studies, including differences between FO and placebo groups up to 60%. Across studies there was a very broad range of net percent changes in fasting insulin.; 83 There was similar heterogeneity in effect in euglycemic and hyperglycemic populations.; 84 1 study of euglycemic participants found no interaction with weight loss (on a weight loss diet). No differences based on covariates could be discerned across studies.; 85 No evidence suggests different effects based on dose or source.; 86 1 study reported no difference in effects at multiple time points to 6 months.; 87 No evidence on sustainment of effect. | From update search: 10 RCTs (1 FO vs. EPA+DHA, 1 n-3 FA+ALA, 1 Mediterranean diet, 1 FO, 2 n-3 FA, 2 EPA+DHA, 1 DHA, 1 walnut) were identified. From experts: 2 RCTs (1 fish oil, fatty fish, lean fish diet vs. no fish control diet; 1 flaxseed vs. wheat germ); 82 Among the FO or EPA/DHA studies, no sig. effect was reported. Another RCT sent from expert showed that subjects who consumed fish oil and fish diets had (median) decreases in fasting insulin, while control subjects did not (no statistical testing was done).; 83 One RCT comparing Mediterranean diet with low-fat diet found that sig. difference was found among diabetic participants, but not among non-diabetic participants.; 84 One RCT that evaluated walnut intakes reported sig. higher fasting insulin in walnut group compared with placebo group, but no sig. diff in HOMA-IR. All other RCTs reported no sig. difference in fasting insulin or HOMA-IR between groups, including the 1 ALA study sent from expert.; 85-87 No new data were found. | One of the experts stated that the findings of the original report are almost or certainly still supported by the evidence; two stated that they are not, one was undecided, one omitted the question, and one stated that they are supported but that the outcome should not be updated. One stated that the findings are not still supported, adding, “A recent review article points out that it might decrease insulin in subjects with non-alcoholic liver disease although the data need to be confirmed with randomized control trials.” | - FO: Possibly out of date (based on minority expert opinion); - ALA: Probably out of date (based on new trials) | Quantitative: FO: N/A ALA: N/A Qualitative: FO: No signal ALA: No signal (or A4, new trials where there were none)
C-reactive protein (CRP)
4 RCTs (4 FO, 0 ALA), 1 cross-sectional (Fish) (Any study); 88 No study found a significant effect of n-3 FA consumption on CRP level.; 89 In one trial no difference in effect was seen among participants with elevated baseline CRP (>2 mg/L); 90 There was no evidence of a dose effect.; 91 CRP levels were unchanged regardless of intervention duration up to 3 months.; 92 No evidence on sustainment of effect. | From our literature search: 8 RCTs (1 herring, 1 DHA, 2 Mediterranean diet, 2 n-3 FA, 1 linseed oil, 1 ALA), 3 cross-sectional (2 n-3, 1 EPA+DHA, 1 non-fried fish, 1 ALA), 1 cohort (fish), 2 NRCS (n-6+fish oil, salmon) From experts: 2 RCTs (1 FO, 1 ALA); 88 (From search) No sig. effect in cohort study, 2 NRCS, and 7 RCTs; 1 RCT, sig. lower CRP in ALA vs. placebo; 1 XS study, lower CRP with increased nonfried fish intake, but not EPA+DHA intake; 1 XS study, lower CRP with increased n-3 FA intake, but not ALA; 1 XS study, sig. association among male exsmokers or female nonsmokers, but not male nonsmokers.; (From experts) 1 RCT, nonsig ALA vs. placebo; 1 RCT, sig. reduction in CRP between pre- and post intervention for DHA group; 89 No new data for effect modification by baseline CRP; 90 No new data for dosage.; 91 No new data for duration of intervention.; 92 1 RCT: sig. decreased CRP in ALA vs. placebo at 1 & 2 y follow-up. | Two of the experts stated that the findings of the original report are almost or certainly still supported by the evidence (one stated that they are generally still true); two were undecided, and one recommended not updating this outcome. | - FO: Possibly out of date (based on new trials); - ALA: Probably out of date (based on new trials) | Quantitative: FO: N/A ALA: N/A Qualitative: FO: No signal ALA: No signal (or A4, new trials where there were none)
Fibrinogen
24 RCTs (22 FO, 3 ALA) (N≥15 [parallel design], N≥10 [crossover]); 93 No consistent effect on fibrinogen levels of n-3 FA consumption compared to control.; 94 Subsets of studies evaluated healthy people, those with CVD or hypertension, dyslipidemia, and diabetes. No consistent difference in effect was seen across studies. But 2 studies found a large net decrease in fibrinogen with n-3 FA in those with hyperlipoproteinemia types IIb or IV, and a sig. net increase in those with insulin-dependent DM, respectively.; 95 5 studies found no association in effect with various factors including sex, baseline and change in weight, baseline blood pressure, changes in lipids or insulin, or cardiovascular, lipid or antithrombotic drug use, wine consumption, high- or low-fat diets.; 96 There was no consistent dose effect or difference by n-3 source; 97 There was no apparent difference in effect across 2 weeks to 2 years of consumption.; 98 Two studies, which found no effect on fibrinogen, also found no further change 4 weeks or 6 months after stopping the intervention. | 93 6 RCTs (1 FO, 1 herring, 2 n-3 FA, 1 ALA, 1 ALA vs. EPA/DHA vs. control) from update search and 1 RCT (flaxseed vs. wheat germ) from experts were identified. No study reported sig effect.; 94-98 No new data were found. | Three of the experts were undecided; three recommended not updating this outcome. | - FO: Still valid; - ALA: Still valid | Quantitative: FO: N/A ALA: N/A Qualitative: FO: No signal ALA: No signal
Factor VII
19 RCTs (17 FO, 3 ALA) (N≥15 [parallel design], N≥10 [crossover]); 99 There was no consistency in effect across studies. Any net changes were small (<7%).; 100 Two of three studies of people with diabetes found a statistically significant net increase in factor VII. No consistent effects were found in different populations.; 101 Possible associations between effect size and covariates were analyzed by 3 studies, but there were no consistent findings.; 102 Across studies, there was no evidence of a dose effect. Within studies there was no evidence of different effects with different n-3 FA sources.; 103 Across studies, duration of intervention had no effect.; 104 In one study, there continued to be no effect on factor VII 1 month after stopping the intervention. | 99 3 RCTs (2 n-3 FA, 1 control vs. ALA vs. EPA/DHA of a variety of treatment combinations were identified. No sig effect of n-3 FA on factor VII was reported.; 100-104 No new data were found. | One of the experts stated that the findings of the original report are almost or certainly still supported by the evidence; two were undecided and three recommended not updating this outcome. | - FO: Still valid; - ALA: Still valid | Quantitative: FO: N/A ALA: N/A Qualitative: FO: No signal ALA: No signal
Factor VIII
5 RCTs (4 FO, 1 ALA) (N≥5); 105 There was no consistency in effect across studies.; 106 The single stuffy of insulin dependent diabetics found a larger, though non-significant net increase of factor VIII than studies of the general population.; 107 One study found no association between effect size and sex or Hgb A1c in insulin dependent diabetics who were also taking aspirin.; 108 One study found no fish oil dose effect. The evidence across studies was unclear regarding differential effects based on source or type of n-3 FA.; 109 Three studies found no consistent effect across a range of intervention durations from 3 weeks to 12 months.; 110 In one study there was no change in factor VIII 1 and 2 months after stopping the intervention. | 105-110 No new data were found. | One of the experts stated that the findings of the original report are almost or certainly still supported by the evidence; two were undecided and three recommended not updating this outcome. | - FO: Still valid; - ALA: Still valid | Quantitative: FO: N/A ALA: N/A Qualitative: FO: No signal ALA: No signal
von Willebrand Factor (vWF)
9 RCTs (8 FO, 1 ALA) (N≥5); 111 Most studies found a net decrease in vWF (up to 13%), though only one study found a statistically significant difference.; 112 No clear pattern in effect was seen across populations.; 113 The studies do not allow conclusions about the effect of covariates.; 114 One study each found no dose effect and no difference between fish oil type. There was no consistent effect based on dose or type across studies.; 115 Two studies found no consistent effect across a range of intervention durations from 3 weeks to 12 months.; 116 In one study there was no change in factor VIII 1 and 2 months after stopping the intervention. | 111 No sig effect was found is any of the 3 RCTs identified. In one RCT, stratified analysis by presence or absence of diet intervention did not change the results.; 112-116 No new data were found. | Three of the experts were undecided and three recommended not updating this outcome. | - FO: Still valid; - ALA: Still valid | Quantitative: FO: N/A ALA: N/A Qualitative: FO: No signal ALA: No signal
Platelet aggregation
11 RCTs (8 FO, 5 ALA) (N≥15 [parallel design], N≥10 [crossover]); 117 Large heterogeneity of methods to measure platelet aggregation.; 118 “Heterogeneous effects … depending on aggregating agent, dose of the agent, and measurement metric used. [In] most studies either no effect on platelet aggregation with n-3 FA or no difference in effect ….”; 119 No evidence of differential effects in different populations, by health status, weight, age, or sex. or covariates smoking and alcohol consumption, within and across studies.; 120 No study compared different doses of n-3 FA. No dose effect was seen across studies. Two studies disagreed whether platelet aggregation differed with fish oil or ALA. One concluded that pure DHA is less potent at reducing aggregation than fish oil or dietary fish at moderate doses.; 121 No clear effect of time consuming n-3 FA was seen in 3 studies.; 122 One study found that one measure of platelet aggregation did not return to baseline during a 12 week follow-up after stopping the trial; though other tests did. | 117 From update search: 2 RCTs (1 FO, 1 ALA) and 1 non-randomized comparative study (FO) reported a variety of platelet aggregation measurements.; From experts: 1 RCT (1 g n-3 with aspirin and clopidogrel vs. placebo with aspirin and clopidogrel) platelet aggregation to ADP was sig. reduced, but platelet aggregation to arachidonic acid was not sig. different.; 118 One RCT and one comparative study found no sig diff among treatment groups in one measure, but sig diff in another measure.; 119 In one study, collagen induced platelet aggregation was sig reduced in an older group (age 45-69) but not in younger group (age 18-29). There were no sig diff between treatment groups in thrombin aggregation in both age groups.; 120 No new data on dosage were found.; 121 No new data on the effect of time consuming n-3 FA were found.; 122 No new data were found. | Three of the experts stated that the findings of the original report are almost or certainly still supported by the evidence; two were undecided and one omitted the question. One omitted the question, but added that “combination data is important to add here” and that “safety is clear in combination with other agents.” | - FO: Still valid; - ALA: Still valid | Quantitative: FO: N/A ALA: N/A Qualitative: FO: No signal ALA: No signal
Coronary arteriography
12 RCTs (12 FO, 0 ALA) (N≥5); 123 “Overall, although there is heterogeneity among studies, there is a trend toward a net reduction of coronary artery restenosis with fish oil supplementation.” Random effects model RR = 0.87 (95% CI 0.73, 1.05).; 124 All studies included patients undergoing PTCA. The studies that performed multivariate analyses including diabetes, lipid and cardiovascular variables generally found no association between these covariates and restenosis rates. Two studies found no difference between men and women.; 125 The heterogeneity of the studies was not explained by either dose or treatment duration.; 126 No evidence on sustainment of effect. | No new data were found. | Two of the experts stated that the findings of the original report are almost or certainly still supported by the evidence; one stated that they do not, two were undecided, and one omitted the question. | - FO: Possibly out of date (based on minority expert opinion); - ALA: Still valid | Quantitative: FO: N/A ALA: N/A Qualitative: FO: No signal ALA: No signal
Carotid intima media thickness (IMT)
1 RCT (FO), 1 longitudinal cohort (ALA), 2 cross-sectional (1 dietary ALA, 1 fishing vs farming village) (Any study); 127 The only RCT of fish oil found no significant net effect on carotid IMT. The longitudinal study of ALA was consistent with the RCT. The cross sectional studies both found that higher n-3 FA intake was associated with thinner IMT.; 128 Insufficient evidence to evaluate subpopulations, covariates, dose effect, source effect, exposure duration, or sustainment of effect. | 127 2 RCTs (1 ALA, 1 EPC) found no sig effect on IMT.; 2 ALA cross-sectional studies: 1 sig and 1 NS; 1 non-fried fish cross-sectional study: no sig effect; 2 n-3 FA cross-sectional studies: sig lower IMT with increased n-3 FA intakes.; 1 cross-sectional study found sig lower IMT with increased EPA, DPA, or DHA intakes.; 128 No new data on subpopulations, covariates, dose effect, exposure duration, or sustainment of effect were found. | Two of the experts stated that the findings of the original report are almost or certainly still supported by the evidence; three were undecided and one omitted the question. | - FO: Still valid; - ALA: Probably out of date (based on 1 new trial) | Quantitative: FO: N/A ALA: N/A Qualitative: FO: No signal ALA: No signal (or A4, new trial where there were none)
Exercise tolerance testing
3 RCTs (3 FO, 0 ALA), 3 longitudinal cohorts (3 FO, 0 ALA) (Any study); 129 Studies suggest that fish oil consumption may benefit exercise capacity among patients with coronary artery disease, although the effect may be small.; 130 Insufficient evidence to evaluate subpopulations, covariates, dose effect, source effect, exposure duration, or sustainment of effect. | 129 No new data were found.; 130 No new data were found. | Three of the experts stated that the findings of the original report are almost or certainly still supported by the evidence; one was undecided, one recommended not updating this outcome, and one omitted the question. | - FO: Still valid; - ALA: Probably out of date (based on 1 new trial) | Quantitative: FO: N/A ALA: N/A Qualitative: FO: No signal ALA: No signal
Heart rate variability
2 RCTs (2 FO, 0 ALA), 1 cross-sectional (FO) (Any study); 131 The 3 studies, all by the same set of investigators, found that there was no significant effect of fish oil on heart rate variability in healthy volunteers, but may increase (improve) heart rate variability in survivors of myocardial infarction.; 132 There is possible evidence of a dose effect. | From our literature search: 2 RCTs (n-3 FA) and 1 cohort study (dark fish, n-3 FA) From experts: 3 RCTs (n-3 FA); 131 The 3 studies from the literature search did not find sig effect on heart rate variability. The 3 studies from the experts all found significant improvements in heart rate variability with fish oil.; 132 1 study (from experts) found a dose effect. | Two of the experts stated that the findings of the original report are almost or certainly still supported by the evidence; two were undecided, one recommended not updating this outcome, and one omitted the question. One agreed, adding that there is “more data in support of improved HRV.” | - FO: Probably out of date (based on minority expert opinion, 1 new trial from literature search, and 3 new trials from experts that disagreed with report); - ALA: Still valid | Quantitative: FO: N/A ALA: N/A Qualitative^b^: FO: No signal ALA: No signal
Additional risk factors suggested:; - Suppression of arrhythmias; - Specific cardiac arrhythmias (e.g., atrial vs. ventricular); - Lipoprotein-associated phospholipase A2 (Lp-PLA2).

a Discrepancy between “B1” and “No Signal” is due to one large trial that reported no significant effect, but from reported data changed the meta-analysis from nonsignificant to significant.

b Note that the trials found by the experts were not included in the Ottawa qualitative analysis.

ALA = alpha linolenic acid; BMI = body mass index; BP = blood pressure; CRP = C-reactive protein; CVD = cardiovascular disease; DBP = diastolic blood pressure; DHA = docosahexaenoic acid; DM = diabetes mellitus; EPA = eicosapentaenoic acid; FA = fatty acid; FO = fish oil; HDL = high-density lipoprotein; Hgb = hemoglobin; LDL = low-density lipoprotein; LP = lipoprotein; PTCA = percutaneous transluminal coronary angiography; RCT = randomized controlled trial; SBP = systolic blood pressure; TC = total cholesterol; TG = triglycerides; vWF = von Willebrand Factor

Table B4 Fish oil matrix, “RAND” versus “Ottawa” methods

| | | “RAND”
| | | Definitely Out of Date | Probably Out of Date | Possibly Out of Date | Still Valid
“Ottawa” | Quantitative Analysis | B1 | | | Total cholesterol Fasting glucose SBP (no DM) | LDL (with caveat) 1 HDL (with caveat) 1
“Ottawa” | Quantitative Analysis | B2 | | | DBP (no DM)
“Ottawa” | Qualitative Analysis | A1
“Ottawa” | Qualitative Analysis | A2
“Ottawa” | Qualitative Analysis | A3
“Ottawa” | Qualitative Analysis | A4
“Ottawa” | Qualitative Analysis | A5
“Ottawa” | Qualitative Analysis | A6
“Ottawa” | Qualitative Analysis | A7
“Ottawa” | No Signal | | | HRV | SBP (w/DM) DBP (w/DM) Fasting insulin CRP Coronary arteriography | Tg Lp (a) Apo A-1 Apo B Apo B-100 LDL Apo-B Hb A1c Fibrinogen Factor VII Factor VIII vWF Platelet aggregation Carotid IMT ETT

Apo=apolipoprotein; CRP=C reactive protein; DBP=diastolic blood pressure; DM=diabetes mellitus (indicating the eligibility criterion); ETT=exercise tolerance testing; Hb A1c=hemoglobin A1c; HDL=high density lipoprotein cholesterol; HRV=heart rate variability; IMT=intima media thickness; LDL=low density lipoprotein cholesterol; Lp (a) =lipoprotein (a); SBP=systolic blood pressure; TG=triglycerides; vWF=von Willebrand factor.

Gray shaded boxes indicate discordance between RAND and Ottawa methods.

1 One very large trial had discordant results with almost all other trials. Our consensus was that this one outlier trial did not invalidate the original overall conclusions.

Table B5 ALA matrix, “RAND” versus “Ottawa” methods

| | | “RAND”
| | | Definitely Out of Date | Probably Out of Date | Possibly Out of Date | Still Valid
“Ottawa” | Quantitative Analysis | B1
“Ottawa” | Quantitative Analysis | B2
“Ottawa” | Qualitative Analysis | A1 | | | Total cholesterol LDL
“Ottawa” | Qualitative Analysis | A2
“Ottawa” | Qualitative Analysis | A3
“Ottawa” | Qualitative Analysis | A4 | | *
“Ottawa” | Qualitative Analysis | A5
“Ottawa” | Qualitative Analysis | A6
“Ottawa” | Qualitative Analysis | A7
“Ottawa” | No Signal | | | SBP^*^ DBP^*^ Hb A1c^*^ Fasting glucose^*^ Fasting insulin^*^ CRP^*^ Carotid IMT^*^ | Apo A-1 Apo B | HDL TG Lp (a) Apo B-100 LDL Apo-B Fibrinogen Factor VII Factor VIII vWF Platelet aggregation Coronary arteriography ETT HRV

Apo = apolipoprotein; CRP = C reactive protein; DBP = diastolic blood pressure; DM = diabetes mellitus (indicating the eligibility criterion); ETT = exercise tolerance testing; Hb A1c = hemoglobin A1c; HDL = high density lipoprotein cholesterol; HRV = heart rate variability; IMT = intima media thickness; LDL = low-density lipoprotein cholesterol; Lp (a) = lipoprotein (a); SBP = systolic blood pressure; TG = triglycerides; vWF = von Willebrand factor.

Gray shaded boxes indicate discordance between RAND and Ottawa methods.

* Original review had no studies. Updated search found small new trials found for each. Thus, these could be interpreted as having an A4 signal.

Of 6 experts, votes to not update outcomes:

Lipoprotein (a) | 1
Apolipoprotein A-1 | 1
Apolipoprotein B | 1
Apolipoprotein B-100 | 2
LDL Apolipoprotein B | 1
Fasting insulin | 1
C reactive protein | 1
Fibrinogen | 3
Factor VII | 3
Factor VIII | 3
Exercise tolerance testing | 1
Heart rate variability | 1

From 6 experts, additional cardiovascular risk factors or intermediate markers suggested for updated report:

- Cardiac arrhythmias (both atrial and ventricular)
- Lipoprotein-associated phospholipase A2 (Lp-PLA2).