# Search Strategies and Literature Flow

## Search Strategies

Table A1 Search terms to identify human studies of omega-3 FA and cancer for omega-3s and cancer

Search dates: 2003–May 25, 2010 and updated with the Nutrition and Cancer search on June 28, 2010

Tumor Incidence and Outcomes After Cancer Treatment
1. exp fatty acids, omega-3/; 2. fatty acids, essential/; 3. Dietary Fats, Unsaturated/; 4. linolenic acids/; 5. exp fish oils/; 6. (n 3 fatty acid$ or omega 3).tw.; 7. docosahexa?noic.tw,hw,rw.; 8. eicosapenta?noic.tw,hw,rw.; 9. (linolenate or cervonic or timnodonic).tw,hw,rw.; 10. menhaden oil$.tw,hw,rw.; 11. (mediterranean adj diet$).tw.; 12. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.; 13. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.; 14. (fish adj2 oil$).tw.; 15. (cod liver oil$ or marine oil$ or marine fat$).tw.; 16. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.; 17. (fish consumption or fish intake or (fish adj2 diet$)).tw.; 18. diet$ fatty acid$.tw.; 19. or/1-19; 20. dietary fats/; 21. (randomized controlled trial or clinical trial or controlled clinical trial or evaluation studies or multicenter study).pt.; 22. random$.tw.; 23. exp clinical trials/ or evaluation studies/; 24. follow-up studies/ or prospective studies/; 25. or/22-25; 26. 21 and 26; 27. (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega).tw.; 28. (omega 3 or n 3).mp.; 29. (polyunsaturated fat$ or pufa or dha or epa or long chain or longchain or lc$).mp.; 30. 29 and 30; 31. 20 or 27 or 28 or 31; 32. exp neoplasms/; 33. (neoplasm$ or cancer$ or tumour$ or tumor$ or carcinoma$ or malignanc$).tw.; 34. 33 or 34; 35. 32 and 35

Journals used for the update search for the current report:

1. “Annals of internal medicine”.jn. (25697)
2. Bmj.jn. (51943)
3. Jama.jn. (61018)
4. (Lancet or “lancet oncology”).jn. (119986)
5. “New england journal of medicine”.jn. (62986)
6. “American journal of clinical nutrition”.jn. (16580)
7. “European jourSnal of clinical nutrition”.jn. (4067)
8. “Jpen journal of parenteral & enteral nutrition”.jn. (3426)
9. “American journal of public health”.jn. (17424)
10. “American journal of epidemiology”.jn. (10650)
11. “Bmc cancer”.jn. (1930)

Table A2 Search terms to identify human studies of omega-3 FA and cognitive function

Search dates: 2003–May 28, 2010 but replaced with a later search that had no journal limits on June 28, 2010

Core search strategy (taken from original 2005 omega-3 report)
1. exp fatty acids, omega-3/
2. fatty acids, essential/
3. Dietary Fats, Unsaturated/
4. linolenic acids/
5. exp fish oils/
6. (n 3 fatty acid$ or omega 3).tw
7. docosaheca?noic.tw,hw,rw
8. eicosapenta?noic.tw,hw,rw
9. alpha linolenic.tw,hw,rw.
10. (linolenate or cervonic or timnodonic).tw,hw,rw.
11. menhaden oil$.tw,hw,rw
12. (mediterranean adj diet$).tw.
13. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.
14. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.
15. (fish adj2 oil$).tw.
16. (cod liver oil$ or marine oil$ or marine fat$).tw.
17. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.
18. (fish consumption or fish intake or (fish adj2 diet$)).tw.
19. diet$ fatty acid$.tw.
20. or/1-19
21. dietary fats/
22. (randomized controlled trial or clinical trial or controlled clinical trial or evaluation studies or multincenter study).pt.
23. random$.tw.
24. exp clinical trials/or evaluation studies/
25. follow-up studies/ or prospective studies/
26. or/22-25
27. 21 and 26
28. (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega).tw.
29. (omega 3 or n 3).mp.
30. (polyunsaturated fat$ or pufa or dha or epa or long chain or long chain or lc$).mp.
31. 29 and 30
32. 20 or 27 or 28 or 31

Literature searches by disease category (taken from original 2005 omega-3 report)
Neurology
1. exp fatty acids, omega-3/v
2. fatty acids, essential/
3. Dietary Fats, Unsaturated/
4. linolenic acids/
5. exp fish oils
6. (n 3 fatty acid$ or omega 3).tw.
7. docosahexa?noic.tw.hw.rw.
8. elcosapenta?noic.tw.hw.rw.
9. alpha linolenic.tw.hw.rw
10. (linolenate or cervonic or timnodonic).tw,hw,rw.
11. menhaden oil$.tw, hw,rw.
12. (Mediterranean adj diet$).tw.
13. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.
14. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.
15. (fish adj2 oil$).tw.
16. (cod liver oil$ or marine oil$ or marine fat$).tw.
17. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.
18. (fish consumption or fish intake or (fish adj2 diet $)).tw.
19. diet$ fatty acid$.tw.
20. or/1019
21. dietary fats/
22. (randomized controlled trial or clinical trial or controlled clinical trial or evaluation studies or multicenter study).pt.
23. random$.tw.
24. exp clinical trials/or evaluation studies/
25. follow-up studies/ or prospective studies/
26. or/22-25
27. 21 and 26
28. exp Aging/
29. Aged/
30. (aging or aged or geriatric$).tw.
31. or/28-30
32. 27 and 31
33. limit 27 to “all aged <65 and over>”
34. 32 or 33
35. exp Nervous System Disease
36. Alzheimer Disease/
37. exp Dementia/
38. parkinson disease/ or Parkinson disease, secondary/
39. parkinson disease/ or Parkinson disease, secondary/
40. exp Multiple Sclerosis /
41. exp Guillain-Barre Syndrome/
42. (alzheimer or parkinson or dementia or multiple sclerosis or guillain barre).tw.
43. (neurological disease$ or neurological disorder$).tw.
44. (neurological disease$ or neurological disorder$).tw.
45. exp Optic Nerve Diseases/
46. (myopathy or neuropathy).tw.
47. Cognition Disorders/
48. exp Cognition/
49. (cognition or cognitive).tw.
50. or/35-49
51. 27 and 50
52. exp fatty acids, omega-3/
53. fatty acids, essential/
54. Dietary Fats, Unsaturated/
55. linolenic acids/
56. exp fish oils/
57. (n 3 fatty acid$ or omega 3).tw.
58. docosahexa?noic.tw,hw,rw.
59. eicosapenta?noic.tw,hw,rw.
60. alpha linolenic.tw,hw,rw
61. (linolenate or cervonic or timnodonic).tw,hw,rw.
62. menhaden oil$.tw,hw,rw
63. ((Mediterranean adj diet$).tw.
64. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.
65. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.
66. (fish adj2 oil$).tw.
67. (cod liver oil$ or marine oil$ or marine fat$).tw.
68. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.
69. (fish consumption or fish intake or (fish adj2 diet$)).tw.
70. diet$ fatty acid$.tw.
71. or/52-70
72. dietary fats/
73. (randomized controlled trials or clinical trial or controlled clinical trial or evaluation studies or multicenter study).pt.
74. random$.tw.
75. exp clinical trials/ or evaluation studies/
76. follow-up studies/ or prospective studies/
77. or/73-76
78. 72 and 77
79. (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega).tw.
80. (omega 3 or n 3).mp
81. (polyunsaturated fat$ or pufa or dha or epa or long chain or longchain or lc$).mp.
82. 80 and 81
83. 71 or 78 or 79 or 82
84. 83 and 50
85. 84 not 51
86. 83 and 31
87. 86 not 34
88. limit 87 to “all aged <65 and over>

Journals used for the update search for the current report (for May 28, 2010 search):

1. Limit 62 to “core clinical journals (aim)” (132)
2. “American journal of epidemiology”.jn. (10671)
3. “European journal of clinical nutrition”.jn. (4082)
4. “Jpen journal of parenteral & enteral nutrition”.jn. (3426)
5. “BMC Geriatrics”.jn. (208)
6. “BMC Neurology”.jn. (315)
7. “Journal of neurology neurosurgery & psychiatry”.jn. (14631)

Table A3 Search terms to identify human studies of omega-3 FA and cardiovascular risk factors

Search dates: 2003–May 25, 2010

1 | exp Fatty Acids, Omega-3/ | 11692
2 | Fatty Acids, Essential/ | 3889
3 | Dietary Fats, Unsaturated/ | 4121
4 | Linolenic Acids/ | 1294
5 | exp Fish Oils/ | 13938
6 | (n 3 fatty acid$ or omega 3).tw. | 7917
7 | docosahexa?noic.tw,hw,rw. | 7027
8 | eicosapenta?noic.tw,hw,rw. | 5784
9 | (linolenate or cervonic or timnodonic).tw,hw,rw. | 569
10 | menhaden oil$.tw,hw,rw. | 424
11 | (mediterranean adj diet$).tw. | 1123
12 | ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw. | 4177
13 | (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw. | 19477
14 | (fish adj2 oil$).tw. | 5899
15 | (cod liver oil$ or marine oil$ or marine fat$).tw. | 908
16 | (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw. | 20386
17 | (fish consumption or fish intake or (fish adj2 diet$)).tw. | 3377
18 | diet$ fatty acid$.tw. | 1432
19 | or/1-18 | 69765
20 | dietary fats/ | 36196
21 | (randomized controlled trial or clinical trial or controlled clinical trial or evaluation studies or multicenter study or meta-analysis).pt. | 760768
22 | random$.tw. | 508629
23 | exp Clinical Trial/ or evaluation studies/ | 741476
24 | follow-up studies/ or prospective studies/ | 641761
25 | or/21-24 | 1520618
26 | 20 and 25 | 4833
27 | (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega).tw. | 221
28 | (omega 3 or n 3).mp. | 42014
29 | (polyunsaturated fat$ or pufa or dha or epa or long chain or longchain or lc$).mp. | 98752
30 | 28 and 29 | 7974
31 | 19 or 26 or 27 or 30 | 74837
32 | exp cardiovascular diseases/ | 1566882
33 | Adhesion molecule expression.mp. | 2085
34 | Angiographic progression.mp. | 101
35 | Angioplast$.mp. | 53559
36 | (atherogen$ or antiartherogen$ or anti-artherogen$).mp. | 20954
37 | (arrhythmi$ or antiarrhythmi$ or anti-arrhythmi$).mp. | 97013
38 | endotheli$.mp. | 229123
39 | exp endothelium, vascular/ | 77800
40 | Beta-thromboglobulin$.mp. | 2639
41 | Cardi$.mp. | 813927
42 | CHD.mp. | 12497
43 | Coronary.mp. | 329921
44 | Hypotens$.mp. | 57619
45 | Hypotriglyceridem$.mp. | 252
46 | heart disease$.mp. | 153264
47 | Myocardial infarct$.mp. | 160737
48 | Platelet adhesi$.mp. | 9519
49 | ((postprandial or post-prandial) adj (lipemia or lipoprotein$)).mp. | 705
50 | Pulmonary Embol$.mp. | 34171
51 | Heart failure$.mp. | 105125
52 | Arteriosclerosi$.mp. | 65056
53 | (cardioprotect$ or cardio-protect$).mp. | 9318
54 | Homocystine/ | 460
55 | exp Homocysteine/ | 10895
56 | homocyst$.mp. | 17060
57 | Cystine/ | 4964
58 | Cystine.mp. | 9344
59 | exp Acute-Phase Proteins/ | 129564
60 | Acute-Phase Protein$.mp. | 7028
61 | Acute-Phase Reaction/ | 2630
62 | Acute-Phase React$.mp. | 5479
63 | exp Blood Coagulation Factor Inhibitors/ | 14042
64 | exp Blood Coagulation Factors/ | 357239
65 | blood coagulation factor$.mp. | 12271
66 | exp Cell Adhesion Molecules/ | 82827
67 | cell adhesion molecule$.mp. | 38891
68 | exp Interleukins/ | 146546
69 | interleukin$.mp. | 196513
70 | Lipid Peroxidation/ | 28060
71 | Lipid Peroxidat$.mp. | 42254
72 | exp Hemostasis/ | 86937
73 | hemosta$.mp. | 37380
74 | haemosta$.mp. | 7481
75 | exp Diagnostic Techniques, Cardiovascular/ | 571881
76 | or/32-75 | 2978721
77 | 31 and 76 | 15703
78 | limit 77 to yr=“2003 - 2010” | 6011
79 | limit 78 to humans | 4102
80 | limit 78 to “in data review” or in process or “pubmed not medline” | 241
81 | 79 or 80 | 4343

Journals used for the update search for the current report:

1. Bmj.jn. (51943)
2. Lancet.jn. (117602)
3. Jama.jn. (61018)
4. “New england journal of medicine”.jn. (62986)
5. “Annals of internal medicine”.jn. (25697)
6. “American journal of clinical nutrition”.jn. (16580)
7. “American journal of cardiology”.jn. (30501)
8. “Arteriosclerosis thrombosis and vascular biology”.jn. (5909)
9. Atherosclerosis.jn. (9082)
10. Atherosclerosis supplements.jn. (165)
11. “Diabetes care”.jn. (12772)
12. “European journal of clinical nutrition”.jn. (4067)
13. Lipids.jn. (6468)
14. “Thrombosis and haemostasis”.jn. (10916)
15. “Thrombosis research”.jn. (9447)
16. “Circulation research”.jn. (13414)
17. “Cardiovascular research”.jn. (8630)
18. “European heart journal”.jn. (11372)
19. “Bmc cardiovascular disorders”.jn. (297)

## Literature Flow Diagrams

Figure A1 Literature flow diagram for cognitive functions (used for both the RAND and Ottawa methods)

Figure A1 is the literature flow diagram depicting the results from the literature search and review on the subject of Cognitive function, which were used for both the RAND and Ottawa methods of assessment. Further description of this figure is provided in Chapter 2 under Literature Search and Data Abstraction.

Figure A2 Literature flow diagram for cancer (used for both the RAND and Ottawa methods)

Figure A2 is the literature flow diagram depicting the results from the literature search and review on the subject of Cancer, which were used for both the RAND and Ottawa methods of assessment. Further description of this figure is described in Chapter 2 under Literature Search and Data Abstraction.

Figure A3 Literature flow diagram for cardiovascular disease factors (used for both the RAND and Ottawa methods)

Figure A3 is the literature flow diagram depicting the results from the literature search and review on the subject of Cardiovascular Disease Factors, which were used for both the RAND and Ottawa methods of assessment. Further description of this figure is described in Chapter 2 under Literature Search and Data Abstraction.