# Appendixes

Appendix A Search Strategies and Literature Flow

Appendix B Summary Tables

Appendix C Evidence Tables

Appendix D Informational Letters