# Acknowledgements

The principal investigators and the research team would like to acknowledge the guidance provided by Paul Coates, director of the National Institutes of Health Office of Dietary Supplements; the assistance of the RAND Evidence-based Practice Center librarian, Roberta Shanman, and the administrative assistant, Patty Smith; and the careful work of the reviewers.