# Results

## Time To Complete the Surveillance Reports

Between June 2011 and June 2012 we evaluated 14 CERs. Table 3 indicates the CERs that were evaluated and the priority they received, the date of their release, and the date of when either the SCEPC or UOEPC sent the assessments to AHRQ. In addition, Table 3 presents the number of days to complete each of the 14 surveillance reports. The mean was 86 days and the median was 74 days, with the majority of reports being completed in 65 to 102 days.

Table 3 Fourteen completed CER topics

CER | CER Topic | Release Date of Original CER | Completion Date for Most Recent Assessment | Days To Complete the Surveillance | Priority
13 | Comparative Effectiveness of Therapies for Clinically Localized Prostate Cancer | 2/1/08 | 5/18/12 | 74 | High
15 | Comparative Effectiveness of Radiofrequency Catheter Ablation for Atrial Fibrillation | 7/6/09 | 11/30/11 | 69 | Low
16 | Comparative Effectiveness of Lipid-Modifying Agents | 9/1/09 | 12/23/11 | 72 | High
17 | Comparative Effectiveness of Medications To Reduce Risk of Primary Breast Cancer in Women | 9/14/09 | 11/08/11 | 119 | Medium
18 | Comparative Effectiveness of Angiotensin Converting Enzyme Inhibitors or Angiotensin II Receptor Blockers Added to Standard Medical Therapy for Treating Stable Ischemic Heart Disease | 10/16/09 | 12/23/11 | 38 | Low
19 | Comparative Effectiveness of Core Needle Biopsy and Open Surgical Biopsy for Diagnosis of Breast Lesions | 12/15/09 | 12/16/11 | 102 | Medium
20 | Comparative Effectiveness and Safety of Radiotherapy Treatments for Head and Neck Cancer | 5/27/10 | 11/4/11 | 75 | Medium
21 | Comparative Effectiveness of In-Hospital Use of Recombinant Factor VIIa for Off-Label Indications vs. Usual Care | 6/1/10 | 2/24/12 | 65 | Low
22 | Comparative Effectiveness of Nonoperative and Operative Treatments for Rotator Cuff Tears | 6/5/10 | 2/24/12 | 65 | Low
23 | Effectiveness of Recombinant Human Growth Hormone (rhGH) in the Treatment of Patients With Cystic Fibrosis | 10/4/10 | 12/16/11 | 100 | Low
25 | Traumatic Brain Injury and Depression | 4/13/11 | 4/10/12 | 161 | Low
26 | Comparative Effectiveness of Therapies for Children with Autism Spectrum Disorders | 4/4/11 | 01/23/12 | 97 | Low
30 | Comparative Effectiveness of Pain Management Interventions for Hip Fracture | 5/17/11 | 4/10/12 | 133 | Low
35 | Comparative Effectiveness of Terbutaline Pump for the Prevention of Preterm Birth | 9/29/2011 | 5/4/12 | 38 | Low

The assessments of 14 CERs that were submitted by the SCEPC or UOEPC can be found on AHRQ's Web site (www.ahrq.gov) where the specific CER is located.

## Assessment Findings

The characteristics of the 14 CERs we assessed and the corresponding surveillance assessment results are presented in Table 4. Briefly, the number of Key Questions (KQs) across the 14 CERs ranged from three (CER No.s 16, 19) to seven (CER Nos. 23, 26). The median number of included studies in the CERs was 107 (range: 14–436). The number of newly identified studies deemed relevant for inclusion in the CERs ranged from 0 to 33, with a median of 15 studies.

Table 4 Characteristics of 14 comparative effectiveness reviews and their updating surveillance assessments

CER Title (AHRQ #) Author Name (Publication Date) [Journal Publication, if Available] | Latest Search Date for CER (Across Databases) | # of Included Studies in CER (Total or Per KQ) | Period Covered by Update Search | # Of New Studies Judged as Relevant for Inclusion in CER | Number of Conclusions Within the Key Questions in CER by Updating Status | | | | | | | | Updating Priority for the CER
CER Title (AHRQ #) Author Name (Publication Date) [Journal Publication, if Available] | Latest Search Date for CER (Across Databases) | # of Included Studies in CER (Total or Per KQ) | Period Covered by Update Search | # Of New Studies Judged as Relevant for Inclusion in CER | KQ# | # Conclusions Up To Date | KQ# | # Conclusions Probably Out of Date | KQ# | # Conclusions Possibly Out of Date | KQ# | # Conclusions Out of Date | Low | Medium | High
Assessed by RAND EPC
Comparative Effectiveness of Therapies for Clinically Localized Prostate Cancer (13) Wilt (February 2008)15 [Association Between Hospital and Surgeon Radical Prostatectomy Volume and Patient Outcomes: A Systematic Review]16 | September 2007 | 436 | January 2007 to March 2012 | 21 | 1 | 11/15 | | | 1 | 2/15 | 1 | 2/15 | | | x
| September 2007 | 436 | January 2007 to March 2012 | 21 | | | | | | | 2 | 1/1 | | | x
| September 2007 | 436 | January 2007 to March 2012 | 21 | 3 | 3/3 | | | | | | | | | x
| September 2007 | 436 | January 2007 to March 2012 | 21 | 4 | 1/3 | | | | | 4 | 2/3 | | | x
Comparative Effectiveness of Medications To Reduce Risk of Primary Breast Cancer in Women (17) Nelson (September 2009)17 [Systematic review: comparative effectiveness of medications to reduce risk for primary breast cancer]18 | January 2009 | 13 (KQ1,KQ3) 70 (KQ2,KQ3) 24 (KQ4) 16 (KQ5) | January 2008 to July 2011 | 3 | 1 | 4/6 | 1 | 2/6 | | | | | | x
| January 2009 | 13 (KQ1,KQ3) 70 (KQ2,KQ3) 24 (KQ4) 16 (KQ5) | January 2008 to July 2011 | 3 | 2 | 6/7 | 2 | 1/7 | | | | | | x
| January 2009 | 13 (KQ1,KQ3) 70 (KQ2,KQ3) 24 (KQ4) 16 (KQ5) | January 2008 to July 2011 | 3 | 3 | 4/5 | 3 | 1/5 | | | | | | x
| January 2009 | 13 (KQ1,KQ3) 70 (KQ2,KQ3) 24 (KQ4) 16 (KQ5) | January 2008 to July 2011 | 3 | 4- 5 | 9/9 | | | | | | | | x
Comparative Effectiveness of Core Needle Biopsy and Open Surgical Biopsy for Diagnosis of Breast Lesions (19) Bruening (December, 2009)19 [Systematic review: comparative effectiveness of core-needle and open surgical biopsy to diagnose breast lesions]20 | September 2009 | 107 (KQ1-2) NA (KQ3) | January 2008 to September 2011 | 19 | 1 | 11/16 | | | 1a | 4/16 | 1 | 1/16 | | x
| September 2009 | 107 (KQ1-2) NA (KQ3) | January 2008 to September 2011 | 19 | 2 | 3/4 | | | 2 | 1/4 | | | | x
| September 2009 | 107 (KQ1-2) NA (KQ3) | January 2008 to September 2011 | 19 | 3 | 1/2 | | | 3 | 1/2 | | | | x
Effectiveness of Recombinant Human Growth Hormone (rhGH) in the Treatment of Patients With Cystic Fibrosis (23) Phung (October 2010)21 [Recombinant human growth hormone in the treatment of patients with cystic fibrosis]22 | April 2010 | 26(KQ1-2, KQ4, KQ6-7) 50 (KQ3) 3(KQ5) | January 2010 to August 2011 | 16 | 1-7 | 40/40 | | | | | | | x
Comparative Effectiveness of Traumatic Brain Injury and Depression (25) Guillamondegui (April 2011)23 | June 2010 | 115 | January 2010 to October 2011 | 29 | 1-6 | 15/15 | | | | | | | x
Therapies for Children With Autism Spectrum Disorders (26) Warren (April 2011)24 [A systematic review of early intensive intervention for autism spectrum disorders]25 | May 2010 | 159 | January 2009 to October 2011 | 15 | 1 | 10/14 | | | 1 | 4/14 | | | x
Therapies for Children With Autism Spectrum Disorders (26) Warren (April 2011)24 [A systematic review of early intensive intervention for autism spectrum disorders]25 | May 2010 | 159 | January 2009 to October 2011 | 15 | 2 | 2/3 | | | 2 | 1/3 | | | x
Therapies for Children With Autism Spectrum Disorders (26) Warren (April 2011)24 [A systematic review of early intensive intervention for autism spectrum disorders]25 | May 2010 | 159 | January 2009 to October 2011 | 15 | 3-7 | 6/6 | | | | | | | x
Pain Management Interventions for Hip Fracture (30) Abou-Setta (May, 2011)26 [Comparative effectiveness of pain management interventions for hip fracture: a systematic review]27 | December 2010 | 98 | January 2008 to November 2011 | 1 | 1 | 7/8 | | | 1 | 1/8 | | | x
Pain Management Interventions for Hip Fracture (30) Abou-Setta (May, 2011)26 [Comparative effectiveness of pain management interventions for hip fracture: a systematic review]27 | December 2010 | 98 | January 2008 to November 2011 | 1 | 2-4 | 39/39 | | | | | | | x
Assessed by Ottawa EPC
Comparative Effectiveness of Radiofrequency Catheter Ablation for Atrial Fibrillation (15) IP (July 2009)28 [Systematic review: comparative effectiveness of radiofrequency catheter ablation for atrial fibrillation]29 | December 2008 | 120 | June 2008 to September 2011 | 33 | 1 | 4/4 | | | | | | | x
| December 2008 | 120 | June 2008 to September 2011 | 33 | 2 | 3/5 | | | 2 | 2/5 | | | x
| December 2008 | 120 | June 2008 to September 2011 | 33 | 3 | 3/4 | | | 3 | 1/4 | | | x
| December 2008 | 120 | June 2008 to September 2011 | 33 | 4 | 6/6 | | | | | | | x
Comparative Effectiveness of Lipid-Modifying Agents (16) Sharma (September 2009)30 [Systematic review: comparative effectiveness and harms of combination therapy and monotherapy for dyslipidemia]31 | May 2009 | 101 | November 2008 to October 2011 | 20 | 1 | 3/13 | | | | | 1 | 10/13 | | | x
Comparative Effectiveness of Lipid-Modifying Agents (16) Sharma (September 2009)30 [Systematic review: comparative effectiveness and harms of combination therapy and monotherapy for dyslipidemia]31 | May 2009 | 101 | November 2008 to October 2011 | 20 | 2 | 34/48 | | | 2 | 14/48 | | | | | x
Comparative Effectiveness of Lipid-Modifying Agents (16) Sharma (September 2009)30 [Systematic review: comparative effectiveness and harms of combination therapy and monotherapy for dyslipidemia]31 | May 2009 | 101 | November 2008 to October 2011 | 20 | 3 | 9/25 | | | 3 | 16/25 | | | | | x
Comparative Effectiveness of Angiotensin Converting Enzyme Inhibitors or Angiotensin II Receptor Blockers Added to Standard Medical Therapy for Treating Stable Ischemic Heart Disease(18) Coleman (October 2009)32 [Systematic review: comparative effectiveness of angiotensin-converting enzyme inhibitors or angiotensin II-receptor blockers for ischemic heart disease]33 | February 2009 | 60 | August 2008 to November 2011 | 12 | 1 | 6/7 | | | 1 | 1/7 | | | x
| February 2009 | 60 | August 2008 to November 2011 | 12 | 2-6 | 28/28 | | | | | | | x
| February 2009 | 60 | August 2008 to November 2011 | 12 | | | 7 | 4/4 | | | | | x
Comparative Effectiveness of In-Hospital Use of Recombinant Factor VIIa for Off-Label Indications vs. Usual Care (21) Yank (May 2010)34 [Systematic review: benefits and harms of in-hospital use of recombinant factor VIIa for off-label indications]35 | August 2009 | 74 | February 2009 to January 2012 | 15 | 2 | 2/3 | | | 2 | 1/3 | | | x
| August 2009 | 74 | February 2009 to January 2012 | 15 | 3a | 8/9 | | | 3a | 1/9 | | | x
| August 2009 | 74 | February 2009 to January 2012 | 15 | 3b | 3/4 | | | 3b | 1/4 | | | x
| August 2009 | 74 | February 2009 to January 2012 | 15 | 4b-c | 9/9 | | | 4a | 1/2 | | | x
Comparative effectiveness and safety of radiotherapy treatments for head and neck cancer (20) Samson (May 2010)36 | September 2009 | 108 | March 2009 to August 2011 | 7 | 1 | 2/3 | | | 1 | 1/3 | | | | x
Comparative effectiveness and safety of radiotherapy treatments for head and neck cancer (20) Samson (May 2010)36 | September 2009 | 108 | March 2009 to August 2011 | 7 | 2 | 1/2 | | | 2 | 1/2 | | | | x
Comparative effectiveness and safety of radiotherapy treatments for head and neck cancer (20) Samson (May 2010)36 | September 2009 | 108 | March 2009 to August 2011 | 7 | | | | | 3 | 1/1 | | | | x
Comparative effectiveness and safety of radiotherapy treatments for head and neck cancer (20) Samson (May 2010)36 | September 2009 | 108 | March 2009 to August 2011 | 7 | 4 | 3/3 | | | | | | | | x
Comparative Effectiveness of Nonoperative and Operative Treatments for Rotator Cuff Tears (22) Sedia (July 2010)37 [Systematic review: nonoperative and operative treatments for rotator cuff tears]38 | September 2009 | 137 | March 2009 to January 2012 | 15 | 1- 6 | 18/18 | | | | | | | x
Comparative Effectiveness of Terbutaline Pump for the Prevention of Preterm Birth (35) Gaudet,(September 2011)39 [Effectiveness of Terbutaline Pump for the Prevention of Preterm Birth. A Systematic Review and Meta-Analysis]40 | April, 2011 | 14 | October 2010 to March 2012 | 0 | 1-6 | 37/37 | | | | | | | x

KQ = Key Question; CER = comparative effectiveness review

Of the 14 CERs, 4 (29 percent) were up to date in the 12 to 59 months following their original search date (CER No.s 22, 23, 25, 35). For the remaining 10 CERs (CER Nos. 13, 15, 16, 17, 18, 19, 20, 21, 26, 30), at least one conclusion within a KQ changed in status from “up-to-date” to “probably/possibly out of date” or “out of date.” In 4 of these 10 CERs (CER Nos. 13, 18, 19, 20), all conclusions within a KQ changed their status from “up-to-date” to “probably/possibly out of date” or “out of date.”

Of the 14 CERs, 2 (14.3 percent) were assigned to high, 3 (21.4 percent) were assigned to medium, and 9 (64.4 percent) were assigned to low priority for updating. Of the 6 CERs released prior to 2010 (meaning more than 18 months prior to start of the Surveillance Program), 2 were judged as being high priority, 2 were judged as being medium priority, and 2 were judged as being low priority for updating. Of the remaining 8, only one was judged as being medium priority for updating. All but 1 of the CERs released within the year prior to the start of the Surveillance Program were judged as being low priority.

The percentage of experts asked who actually responded was also noted. The response rate ranged from 20 percent to 100 percent, with a median of 34.5 percent.

None of the 14 CERs for which we performed the surveillance assessments had an FDA black box warning associated with an agent, device, or procedure that was a topic of the CER (the strongest FDA warning, which indicates a significant risk of a serious or even life-threatening adverse effect). Five CERs had safety communications, adverse effects, and/or label change alerts (CER Nos. 16, 18, 23, 25, 26), none of which was sufficient to impact the updating priority of those CERs. CER No. 16 had a total of six label change alerts and three drug safety communication alerts, CER No. 18 had three alerts, and 3 CERs (Nos. 23, 25, 26) had one alert each.