# References

1 Whitlock EP, Lopez SA, Chang S, et al. AHRQ series paper 3: identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):491-501. [pmid: 19540721].
2 Garritty C, Tsertsvadze A, Tricco AC, et al. Updating systematic reviews: an international survey. PLoS One. 2010;5(4):e9914. [pmid: 20376338].
3 The Cochrane Collaboration. Maintaining your review. 2002. www.cochrane-net.org/openlearning/html/mod19-2.htm. February 7, 2013.
4 French SD, McDonald S, McKenzie JE, et al. Investing in updating: how do conclusions change when Cochrane systematic reviews are updated?. BMC Med Res Methodol. 2005;5:33. [pmid: 16225692].
5 Shekelle P, Eccles MP, Grimshaw JM, et al. When should clinical guidelines be updated?. BMJ. Jul. 21. 2001;323(7305):155-7. [pmid: 11463690].
6 Shekelle PG, Ortiz E, Rhodes S, et al. Validity of the Agency for Healthcare Research and Quality clinical practice guidelines: how quickly do guidelines become outdated?. JAMA. Sep. 26. 2001;286(12):1461-7. [pmid: 11572738].
7 Shekelle PG, Newberry SJ, Maglione M, et al. Assessment of the Need to Update Comparative Effectiveness Reviews: Report of an Initial Rapid Program Assessment (2005-2009). (Prepared by the Southern California Evidence-based Practice Center). Rockville, MD. Agency for Healthcare Research and Quality. October. 2009.
8 Moher D, Tsertsvadze A, Tricco AC, et al. When and how to update systematic reviews. Cochrane Database Syst Rev. 2008;(1):MR000023. [pmid: 18254126].
9 Shojania KG, Sampson M, Ansari MT, et al. How quickly do systematic reviews go out of date? A survival analysis. Ann Intern Med. Aug. 21. 2007;147(4):224-33. [pmid: 17638714].
10 Maclean CH, Issa AM, Newberry SJ, et al. Effects of omega-3 fatty acids on cognitive function with aging, dementia, and neurological diseases. Summary, Evidence Report/Technology Assessment No 114. (Prepared by the Southern California Evidence-based Practice Center under Contract No. 290-02-0003.) AHRQ Publication No. 05-E011-1. Rockville, MD. Agency for Healthcare Research and Quality. February. 2005.
11 Maclean CH, Newberry SJ, Mojica WA, et al. Effects of omega-3 fatty acids on cancer. Summary, Evidence Report/Technology Assessment No 113. (Prepared by the Southern California Evidence-based Practice Center under Contract No. 290-02-0003.) AHRQ Publication No. 05-E010-1. Rockville, MD. Agency for Healthcare Research and Quality. February. 2005.
12 Balk EM, Lichtenstein AH, Chung M, et al. Effects of omega-3 fatty acids on coronary restenosis, intima-media thickness, and exercise tolerance: a systematic review. Atherosclerosis. Feb. 2006;184(2):237-46. [pmid: 16084516].
13 Shekelle PG, Newberry SJ, Wu H, et al. Identifying Signals for Updating Systematic Reviews: A Comparison of Two Methods. Methods Research Report. AHRQ Publication No. 11-EHC042-EF. Agency for Healthcare Research and Quality. Rockville, MD. June. 2011.
14 Chung M, Newberry SJ, Ansari MT, et al. Two methods provide similar signals for the need to update systematic reviews. J Clin Epidemiol. Jun. 2012;65(6):660-8. [pmid: 22464414].
15 Wilt TJ, Shamliyan T, Taylor B, et al. Comparative effectiveness of therapies for clinically localized prostate cancer. Comparative Effectiveness Reviews No. 13. (Prepared by Minnesota Evidence-based Practice Center under Contract No. 290-02-0009.) AHRQ Publication No. 08-EHC010-EF. Rockville, MD. Agency for Healthcare Research and Quality. February. 2008.
16 Wilt TJ, Shamliyan TA, Taylor BC, et al. Association between hospital and surgeon radical prostatectomy volume and patient outcomes: a systematic review. J Urol. 2008;180(3):820-8. [pmid: 18635233].
17 Nelson HD, Fu R, Humphrey L, et al. Comparative effectiveness of medications to reduce risk of primary breast cancer in women [Internet]. Comparative Effectiveness Reviews No. 17. AHRQ Publication No. 09-EHC028-EF. Rockville, MD. Agency for Healthcare Research and Quality. September. 2009. [pmid: 20704040].
18 Nelson HD, Fu R, Griffin JC, et al. Systematic review: comparative effectiveness of medications to reduce risk for primary breast cancer. Ann Intern Med. 2009;151(10):703-15. [pmid: 19920271].
19 Bruening W, Schoelles K, Treadwell J, et al. Comparative effectiveness of core-needle and open surgical biopsy for the diagnosis of breast lesions [Internet]. Comparative Effectiveness Reviews No. 19. AHRQ Publication No. 10-EHC007-EF. Rockville, MD. Agency for Healthcare Research and Quality. December. 2009. [pmid: 20704042].
20 Bruening W, Fontanarosa J, Tipton K, et al. Systematic review: comparative effectiveness of core-needle and open surgical biopsy to diagnose breast lesions. Ann Intern Med. 2010;152(4):238-46. [pmid: 20008742].
21 Phung OJ, Coleman CI, Baker EL, et al. Effectiveness of recombinant human growth hormone (rhGH) in the treatment of patients with cystic fibrosis [Internet]. Comparative Effectiveness Reviews No. 23. AHRQ Publication No. 11-EHC003-EF. Rockville, MD. Agency for Healthcare Research and Quality. October. 2010. [pmid: 21938797].
22 Phung OJ, Coleman CI, Baker EL, et al. Recombinant human growth hormone in the treatment of patients with cystic fibrosis. Pediatrics. 2010;126(5):e1211-e26. [pmid: 20921071].
23 Guillamondegui OD, Montgomery SA, Phibbs FT, et al. Traumatic brain injury and depression [Internet]. Comparative Effectiveness Reviews No. 25. AHRQ Publication No. 11-EHC017-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2011. 2011. [pmid: 21938798].
24 Warren Z, Veenstra-Vanderweele J, Stone W, et al. Therapies for Children With Autism Spectrum Disorders [Internet]. Comparative Effectiveness Reviews No. 26. AHRQ Publication No. 11-EHC029-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2011. [pmid: 21834171].
25 Warren Z, McPheeters ML, Sathe N, et al. A systematic review of early intensive intervention for autism spectrum disorders. Pediatrics. 2011;127(5):e1303-e11. [pmid: 21464190].
26 Abou-Setta AM, Beaupre LA, Jones CA, et al. Pain management interventions for hip fracture [Internet]. Comparative Effectiveness Reviews No. 30. AHRQ Publication No. 11-EHC022-EF. Rockville, MD. Agency for Healthcare Research and Quality. May. 2011. [pmid: 21938799].
27 Abou-Setta AM, Beaupre LA, Rashiq S, et al. Comparative effectiveness of pain management interventions for hip fracture: a systematic review. Ann Intern Med. 2011;155(4):234-45. [pmid: 21844549].
28 Ip S, Terasawa T, Balk EM, et al. Comparative effectiveness of radiofrequency catheter ablation for atrial fibrillation [Internet]. Comparative Effectiveness Reviews No. 15. AHRQ Publication No. 09-EHC015-EF. Rockville, MD. Agency for Healthcare Research and Quality. July. 2009. [pmid: 20704038].
29 Terasawa T, Balk EM, Chung M, et al. Systematic review: comparative effectiveness of radiofrequency catheter ablation for atrial fibrillation. Ann Intern Med. 2009;151(3):191-202. [pmid: 19581635].
30 Sharma M, Ansari MT, Soares-Weiser K, et al. Comparative effectiveness of lipid-modifying agents [Internet]. Comparative Effectiveness Reviews No. 16. AHRQ Publication No. 09-EHC024-EF. Rockville, MD. Agency for Healthcare Research and Quality. September. 2009. [pmid: 20704039].
31 Sharma M, Ansari MT, Abou-Setta AM, et al. Systematic review: comparative effectiveness and harms of combination therapy and monotherapy for dyslipidemia. Ann Intern Med. 2009;151(9):622-30. [pmid: 19884623].
32 Coleman CI, Baker WL, Kluger J, et al. Comparative effectiveness of angiotensin converting enzyme inhibitors or angiotensin II receptor blockers added to standard medical therapy for treating stable ischemic heart disease [Internet]. Comparative Effectiveness Reviews No. 18. AHRQ Publication No. 10-EHC002-EF. Rockville, MD. Agency for Healthcare Research and Quality. October. 2009. [pmid: 20704041].
33 Baker WL, Coleman CI, Kluger J, et al. Systematic review: comparative effectiveness of angiotensin-converting enzyme inhibitors or angiotensin II-receptor blockers for ischemic heart disease. Ann Intern Med. 2009;151(12):861-71. [pmid: 20008762].
34 Yank V, Tuohy CV, Logan AC, et al. Comparative Effectiveness of Recombinant Factor VIIa for Off-Label Indications vs. Usual Care. Comparative Effectiveness Review No. 21. AHRQ Publication No. 10-EHC030-EF. Rockville, MD. Agency for Healthcare Research and Quality. May. 2010.
35 Yank V, Tuohy CV, Logan AC, et al. Systematic review: benefits and harms of in-hospital use of recombinant factor VIIa for off-label indications. Ann Intern Med. 2011;154(8):529-40. [pmid: 21502651].
36 Samson DJ, Ratko TA, Rothenberg BM, et al. Treatments for Head and Neck Cancer. Comparative Effectiveness Review No. 20. (Prepared by Blue Cross and Blue Shield Association Tecnology Evaluation Center Evidence-based Practice Center under Contract No. 290-02-0026.). Rockville, MD. Agency for Healthcare Research and Quality. May. 2010.
37 Seida JC, Schouten JR, Mousavi SS, et al. Comparative effectiveness of nonoperative and operative treatments for rotator cuff tears [Internet]. Comparative Effectiveness Reviews No. 22. AHRQ Publication No. 10-EHC050-EF. Rockville, MD. Agency for Healthcare Research and Quality. July. 2010. [pmid: 21028756].
38 Seida JC, LeBlanc C, Schouten JR, et al. Systematic review: nonoperative and operative treatments for rotator cuff tears. Ann Intern Med. 2010;153(4):246-55. [pmid: 20621893].
39 Gaudet L, Singh K, Weeks L, et al. Terbutaline Pump for the Prevention of Preterm Birth. Comparative Effectiveness Review No. 35. (Prepared by the University of OttawaEvidence-based Practice Center under Contract No. HHSA290-2007-10059I.). AHRQ Publication No. 11-EHC068-EF. Rockville, MD. Agency for Healthcare Research and Quality. September. 2011.
40 Gaudet LM, Singh K, Weeks L, et al. Effectiveness of terbutaline pump for the prevention of preterm birth. A systematic review and meta-analysis. PLoS One. 2012;7(2):e31679. [pmid: 22363704].
41 Tsertsvadze A, Maglione M, Chou R, et al. Updating comparative effectiveness reviews: current efforts in AHRQ's Effective Health Care Program. J Clin Epidemiol. 2011;64(11):1208-15. [pmid: 21684114].
42 Robinson KA, Goodman SN. A systematic examination of the citation of prior research in reports of randomized, controlled trials. Ann Intern Med. 2011;154(1):50-5. [pmid: 21200038].