# Acknowledgments

The authors gratefully acknowledge the peer reviewers for their contributions to this project:

## Peer Reviewers

- Ethan Balk, M.D., Ph.D.
  Tufts Medical Center
  Boston, MA
- Mike Clarke, Ph.D.
  Queens University Belfast
  Belfast, Northern Ireland
- Joseph Lau, M.D.
  Brown University
  Providence, RI