# Discussion

Ideally health care decisions and policy making should be informed and based on the most up-to-date scientific evidence.41 Although the importance of updating systematic reviews has been well recognized internationally, there has been a relative paucity of research and initiatives towards maintaining the currency of systematic reviews.2 An earlier, one-time assessment identified 4 out of 11 AHRQ published CERs as being sufficiently out of date that they should be updated or withdrawn.7 These results indicated a need for the regular surveillance of AHRQ published CERs to assess their current validity. Therefore, the University of Ottawa EPC in collaboration with the Southern California EPC, assisted by ECRI, developed and piloted a system for surveillance and identification of signals for updating CERs published within the AHRQ Effective Health Care Program. This report describes the methodology and preliminary work behind the assessment of the need for updating for 14 AHRQ-funded CERs at least 6 months after their publication.

Our preliminary results indicate that a small proportion of CERs may be in need of urgent updating 1 to 3 years after their last search date. Of the 14 CERs assessed between June 2011 and June 2012, 9 (64 percent) were classified as having low priority for updating and 3 CERs (22 percent) had medium priority for updating. Two CERs (14 percent) were determined to have high priority for updating.

The implementation of the surveillance assessment program to determine the updating status of published AHRQ CERs has faced challenges. The assessment of currency and validity of conclusions for each KQ of a CER was based on the totality of information compiled through multiple sources including the qualitative/quantitative signals, expert opinion, and FDA, Health Canada, and MHRA alerts. Although we used operational and standardized definitions throughout the process to ensure relative consistency in the assessments, human judgment is required to interpret the newly identified evidence in relation to the conclusion of the CER. This judgment is a potential source of variability in the assessment. However, our prior work has shown that in at least one explicit assessment, the inter-rater reliability of these judgments was at least moderate.14

An additional challenge was the variability in presentation among the original CERs. Not all CER executive summaries presented the KQs and corresponding conclusions in an identical or even similar manner (e.g., degree of detail, format, or level of summarization). For example, in some CERs, conclusions for each KQ were stratified by the outcome and/or intervention, resulting in multiple conclusions. In other instances, executive summaries were not sufficiently detailed to be able to extract a specific, clearly formulated conclusion; therefore, the reviewers had to probe the entire body of text of the CER. Moreover, some conclusions were not readily amenable to assessing the need for updating with respect to comparative effectiveness. For example, some conclusions included descriptive information on prevalence of certain risk factors in specific populations.

In a few instances, experts differed in their opinions regarding whether or not a specific conclusion in a specific key question was potentially out of date, and the experts' opinions also differed from what the EPCs concluded was demonstrated in newly identified studies. Such differences may reflect differences in experts' knowledge of their respective content areas (AHRQ CERs enlist input from a diverse set of technical experts for exactly this reason), in how up to date they are in terms of the emerging literature,42 or in interpretation of the clinical importance of new evidence. The surveillance program made a global judgment about how to weight expert opinion when it seemed to differ from the results of the literature search on a case-by-case basis. Additionally, for most CERs, we received responses from fewer than 50 percent of the experts originally contacted; however, since the experts were not a random sample of all potential experts, the implications of this low response rate in terms of bias in the results are not as clear.

To our knowledge, this surveillance assessment project is the first effort of its scale that has applied methods to assess the updating status of evidence-based reports (or systematic reviews) in a structured and standardized manner. The application of these methods has proven to be relatively feasible, efficient, and at the same time a comprehensive and systematic approach for assessing the need for updating individual CERs across a wide range of health interventions. However, it is premature to generalize our findings to a broader population of CERs or systematic reviews, such as the finding that only a small proportion are high priority for updating within 1 to 3 years, and more data are needed on a larger number of CERs. Additionally, the predictive validity of the signals for updating deserve investigation. Such an investigation will be challenging, however, since it would need to assess both the false positive and the false negative outcomes of the signal, as well as adjusting for any new evidence that may accrue from the time the signals were detected until such time as a full update report could be completed. This latter task may often take 12 or more months.

Ideally the results of this surveillance assessment should be electronically linked to the original CER reports and any subsequent journal publications so that readers are advised regarding the CER's (or publication's) updating status and the Agency's assessment of when (and if) any given out-of-date CERs might be updated. We recognize that the decision to update a CER is a complex one, involving competing priorities, resources, and other emergent issues. As such, readers should not view all out-of-date CERs as reaching the same level of priority.

Given these preliminary results, we believe that this approach would potentially help AHRQ and other similar agencies in making informed decisions for prioritizing updating needs across different CERs (or systematic reviews). One of the main future objectives of this program should be to further harmonize and improve the above-described methods in terms of their feasibility, reproducibility, and applicability. The data collection and surveillance over time will allow us to gauge better what is the optimal time period or frequency needed for updating purposes. Among the first 14 CERs, only one released within one year prior to surveillance was classified as anything other than low priority for updating. If these preliminary results are confirmed, then a one year time frame for surveillance may be a more efficient interval for regular assessment.

## Conclusions

We have established a surveillance program that evaluated 14 CERs over the course of 12 months. Regarding the need to update, 2 were classified as high priority, 3 as medium priority, and 9 as low priority, 12 to 59 months after the last search date of the original CER. We have shown that a program for regular and active surveillance of CERs is feasible.