# Examples of “Low,” “Medium,” and “High” Assessments

Appendix A contains examples of three CER Assessment reports, one for a CER deemed low priority for updating, one for a CER deemed medium priority, and one for a CER deemed high priority. The reports are shown in their entirety, including the appendixes that formed part of each report.

Appendix A-1 Example of a “Low” Priority Assessment

Appendix A-2 Example of a “Medium” Priority Assessment

Appendix A-3 Example of a “High” Priority Assessment