# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CER(s): Comparative Effectiveness Review(s)
EPC(s): Evidence-based Practice Center(s)
FDA: U.S. Food and Drug Administration
MHRA: Medicines and Healthcare products Regulatory Agency