# Results

We identified a total of 40 CERs, of which 34 were original CERs and 6 were updates. The list of included CERs is in Appendix A. Because two CERs on diagnostic tests were excluded, we extracted information from the 32 original CERs evaluating interventions that were not exclusively focused on diagnostic tests, plus 1 update CER whose methods and inclusion criteria differed from those of its original CER. Of the 33 extracted CERs, 21 used single group studies in their review. Of the 21 CERs that used single group studies, 10 reviewed only pharmaceutical agents, 1 reviewed only surgical interventions, 1 reviewed radiotherapy treatments, and 9 reviewed multiple types of interventions. Ten (48%) used single group studies to report only harms, 2 (10%) used single group studies to report only benefits, while the remaining 9 (43%) used single group studies for reporting both harms and benefits (Figure 1). There was some indication of differences in the use of single group studies depending on the type of intervention being evaluated (Figure 2), with single group studies used least commonly in evaluating pharmaceutical interventions, and most frequently used for assessing only harms in evaluation of medical devices. However, this interpretation is limited by the small sample size.

Figure 1 The use of single group studies in 33 comparative effectiveness reviews

The 33 reviews are classified in the pie chart according to how they used single-group studies. The percentage of the 33 reviews is listed, followed by the absolute number of reviews in parentheses. Used only for harms: 30% (10); used for both benefits and harms 27% (9); used only for befefits 6% (2); did not use 37% (12).

Figure 2 The use of single group studies in comparative effectiveness reviews by type of interventions assessed

Five pie charts are shown, one each for the five categories of intervention being evaluated followed by the absolute number of reviews in parentheses. Within each pie chart, for each the four types of use of single group studies, the percentage of the total number of reviews is listed, followed by the absolute number of reviews in parentheses. Thirty reviews assessed pharmaceuticals; 5 surgery; 7 behavioral interventions; and 5 other interventions. (Some reviews evaluated more than one intervention.). The four types of use of the single-group studies are the same as in Figure 1: did not use (lightest gray shading), used only for harms (next lightest gray shading), used for both benefits and harms (dark gray shading), or used only for benefits (darkest gray shading, but not relevant for the surgery and medical devices interventions).

It is noteworthy that not all of the 21 CERs that included single group studies provided an explicit rationale for doing so (Table 1). Of the 11 that did, the reasons cited included provision of supplementary long-term effect data on surgery, hypothesis generation, and addressing a paucity of existing comparative studies. Of the 12 CERs that did not include single group studies, three provided reasons for excluding these types of studies. They included specific concerns about confounding; avoidance of bias; and that sufficient data were expected from comparative studies. We were not able to determine whether the decisions to include or exclude single group studies were made a priori or post hoc.

Table 1 Characteristics of reviewed comparative effectiveness reviews prepared by EPCs

Characteristics | Result n (%), Unless Otherwise Stated
Total number of CERs reviewed | 33
Year of publication, range | 2005–2011
Included single group studies | 21 (64)
Stated rational for including single group studies | 11/21 (52)
Stated rationale for including single group studies for benefits | 6/11 (55)
Stated rationale for including single group studies for harms | 8/19 (42)
Methods
Planned to quantitatively synthesize single group studies | 1 (5)
Planned to quantitatively combine single group studies and comparative studies | 0 (0)
Specified the reasons for using single group studies in quantitative analysis | 2 (10)
Planned to qualitatively combine single group studies and comparative studies | 5 (24)
Describe their methods for assessing risk of bias/quality of individual studies | 21 (100)
Explicitly describe their methods to assess the risk of bias/quality of included single group studies | 12 (57)
Results
Clearly provided the total number of studies included | 20 (95)
Total studies included, median (25^th^–75^th^ percentile) | 128 (74–200)
Clearly provided the number of single group studies included | 14 (67)
Total single group studies included, median (25^th^–75^th^ percentile) | 21 (8–71)
Assessed strength of evidence for the Key Question | 18 (86)
Used single group studies to determine strength of evidence | 8 (44)
Quantitatively synthesized single group studies for efficacy/effectiveness | 0 (0)
Quantitatively combined single group studies with comparative studies for efficacy/effectiveness | 0 (0)
Quantitatively synthesized single group studies for harms | 0 (0)
Quantitatively combined single group studies with comparative studies for harms | 0 (0)
Described the syntheses of the effects from single group studies adjacent to the syntheses of comparative studies | 5 (24)
Described the syntheses of the harms from single group studies adjacent to the syntheses of comparative studies | 9 (43)

CER = comparative effectiveness review; EPC = Evidence-based Practice Center

The median number of single group studies included in the CERs was 21 (interquartile range 8, 71). Notably, none of the 21 CERs that included single group studies quantitatively synthesized single group studies for any outcomes, nor did they attempt to quantitatively combine results from these studies with those from comparative studies. Eighteen of the 21 CERs that included single group studies conducted an assessment of the strength of evidence, and single group studies were used to determine the strength of the evidence in 44 percent of these reviews.

Terms used to describe single group studies in the CERs included “cohort study,” “observational study,” “single arm study,” “noncomparative observational study,” and “case study” (Appendix A).

A summary table of the use of single arm studies in the CERs reviewed is presented in Appendix A, including the title of the reports and the types of interventions, whether single group studies were used to address benefits or harms, the rationale for the inclusion of single group studies, and the terms used to describe single group study.