# References

1 Sackett DL, Rosenberg WM, Gray JA, et al. Evidence based medicine: what it is and what it isn't. 1996. Clin Orthop Relat Res. Feb. 2007;455:3-5. [pmid: 17340682].
2 Campbell D, Stanley J. Experimental and quasi-experimental designs for research. Chicago, IL. Rand-McNally. 1963.
3 Gill AL, Bell CN. Hyperbaric oxygen: its uses, mechanisms of action and outcomes. [Review]. QJM. Jul. 2004;97(7):385-95. [pmid: 15208426].
4 Janne PA, Gurubhagavatula S, Yeap BY, et al. Outcomes of patients with advanced non-small cell lung cancer treated with gefitinib (ZD1839, “Iressa”) on an expanded access study. Lung Cancer. May. 2004;44(2):221-30. [pmid: 15084387].
5 Miller MA, Ulisney K, Baldwin JT. INTERMACS (Interagency Registry for Mechanically Assisted Circulatory Support): a new paradigm for translating registry data into clinical practice. J Am Coll Cardiol. Aug. 24. 2010;56(9):738-40. [pmid: 20723804].
6 Agency for Healthcare Research and Quality. Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. 2007. Version 1.0. 2007.
7 Hills M, Armitage P. The two-period cross-over clinical trial. Br J Clin Pharmacol. Jul. 1979;8(1):7-20. [pmid: 552299].
8 Lathyris DN, Trikalinos TA, Ioannidis JP. Evidence from crossover trials: empirical evaluation and comparison against parallel arm trials. [Review]. Int J Epidemiol. Apr. 2007;36(2):422-30. [pmid: 17301102].
9 Woods JR, Williams JG, Tavel M. The two-period crossover design in medical research. Ann Intern Med. Apr. 1. 1989;110(7):560-66. [pmid: 2923388].
10 Bruening W, Launders J, Pinkney N, et al. Effectiveness of Noninvasive Diagnostic Tests for Breast Abnormalities [Internet]. Rockville, MD. Agency for Healthcare Research and Quality. 2006. Feb. Report No.: 06-EHC005-EF. [pmid: 20704043].
11 Bruening W, Schoelles K, Treadwell J, et al. Comparative Effectiveness of Core-Needle and Open Surgical Biopsy for the Diagnosis of Breast Lesions [Internet]. Rockville, MD. Agency for Healthcare Research and Quality. 2012. [pmid: 20704042].
12 Evans SR. Clinical trial structures. J Exp Stroke Transl Med. Feb. 9. 2010;3(1):8-18. [pmid: 21423788].
13 Miller DW, Martin BC, Loo CM. Sumatriptan and lost productivity time: a time series analysis of diary data. Clin Ther. Nov. 1996;18(6):1263-75. [pmid: 9001842].
14 Glasziou P, Chalmers I, Rawlins M, et al. When are randomised trials unnecessary? Picking signal from noise. BMJ. Feb. 17. 2007;334(7589):349-51. [pmid: 17303884].
15 Wasserfallen JB, Livio F, Zanetti G. Acute rhinosinusitis: a pharmacoeconomic review of antibacterial use. [Review]. Pharmacoeconomics. 2004;22(13):829-37. [pmid: 15329029].
16 Pastula DM, Coffman CJ, Allen KD, et al. Factors associated with survival in the National Registry of Veterans with ALS. Amyotroph Lateral Scler. Oct. 2009;10(5-6):332-38. [pmid: 19922120].
17 Testa D, Lovati R, Ferrarini M, et al. Survival of 793 patients with amyotrophic lateral sclerosis diagnosed over a 28-year period. Amyotroph Lateral Scler Other Motor Neuron Disord. Dec. 2004;5(4):208-12. [pmid: 15799548].
18 Iezzoni LI, Shwartz M, Moskowitz MA, et al. Illness severity and costs of admissions at teaching and nonteaching hospitals. JAMA. Sep. 19. 1990;264(11):1426-31. [pmid: 2391739].
19 Jais P, Hocini M, Hsu LF, et al. Technique and results of linear ablation at the mitral isthmus. Circulation. Nov. 9. 2004;110(19):2996-3002. [pmid: 15520313].
20 Ip S, Chung M, Trikalinos T, et al. Screening for Bilirubin Encephalopathy. Rockville, MD. Agency for Healthcare Research and Quality. 2009. Oct. [pmid: 20722171].
21 Bhutani VK, Johnson LH, Schwoebel A, et al. A systems approach for neonatal hyperbilirubinemia in term and near-term newborns. JOGNN - J Obstet Gynecol Neonatal Nurs. Jul. 2006;35(4):444-55. [pmid: 16881988].
22 Eggert LD, Wiedmeier SE, Wilson J, et al. The effect of instituting a prehospital-discharge newborn bilirubin screening program in an 18-hospital health system. Pediatrics. May. 2006;117(5):e855-e862. [pmid: 16651290].
23 Petersen JR, Okorodudu AO, Mohammad AA, et al. Association of transcutaneous bilirubin testing in hospital with decreased readmission rate for hyperbilirubinemia. Clin Chem. Mar. 2005;51(3):540-44. [pmid: 15738516].
24 Tang H, Foster NR, Grothey A, et al. Comparison of error rates in single-arm versus randomized phase II cancer clinical trials. J Clin Oncol. Apr. 10. 2010;28(11):1936-41. [pmid: 20212253].
25 Wang J, Imai K, Engelgau MM, et al. Secular trends in diabetes-related preventable hospitalizations in the United States, 1998-2006. Diabetes Care. Jul. 2009;32(7):1213-17. [pmid: 19366966].
26 Thall PF, Simon R. Incorporating historical control data in planning phase II clinical trials. Stat Med. Mar. 1990;9(3):215-28. [pmid: 2188324].
27 Williams DA. Extra-Binomial Variation in Logistic Linear Models. Journal of the Royal Statistical Society Series C (Applied Statistics). 1982;31(2):144-8.
28 Vickers AJ, Ballen V, Scher HI. Setting the bar in phase II trials: the use of historical data for determining “go/no go” decision for definitive phase III testing. Clin Cancer Res. Feb. 1. 2007;13(3):972-76. [pmid: 17277252].
29 Taylor JM, Braun TM, Li Z. Comparing an experimental agent to a standard agent: relative merits of a one-arm or randomized two-arm Phase II design. Clin Trials. 2006;3(4):335-48. [pmid: 17060208].
30 Pond GR, Abbasi S. Quantitative evaluation of single-arm versus randomized phase II cancer clinical trials. Clin Trials. Jun. 2011;8(3):260-69. [pmid: 21511687].
31 Sordella R, Bell DW, Haber DA, et al. Gefitinib-sensitizing EGFR mutations in lung cancer activate anti-apoptotic pathways. Science. Aug. 20. 2004;305(5687):1163-67. [pmid: 15284455].
32 Lynch TJ, Bell DW, Sordella R, et al. Activating mutations in the epidermal growth factor receptor underlying responsiveness of non-small-cell lung cancer to gefitinib. N Engl J Med. May. 20. 2004;350(21):2129-39. [pmid: 15118073].
33 Greenland S, Lash TL. Bias analysis. Rothman KJ, Greenland S, Lash TL, editors. Modern Epidemiology. 3rd ed. Philadelphia. Lippincott-Williams-Wilkins. 2008:345-80.
34 Norris S, Atkins D, Bruening W, et al. Selecting Observational Studies for Comparing Medical Interventions. Agency for Healthcare Research and Quality. Methods Guide for Comparative Effectiveness Reviews. Rockville, MD. 2008. [pmid: 21433401]. www.effectivehealthcare.ahrq.gov/ehc/products/196/454/MethodsGuideNorris_06042010.pdf.