# Methods

The purpose of the following empirical evaluation is to understand how EPCs have used single group studies in their CERs. Because there was no single term used consistently across EPCs to describe these types of studies, we reviewed the Methods section of each published CER to search for relevant descriptions (e.g., noncomparative cohort). These descriptions are provided in Appendix A. Crossover studies were excluded from this review because these designs are well-characterized and their properties have been extensively discussed in the literature.7-9

We identified all published CERs prepared for the Effective Health Care Program through searches of the Effective Health Care Web site (www.effectivehealthcare.ahrq.gov). The last search was conducted on January 10, 2012. We excluded CERs at the draft stage at the time of the last search because draft reports have not been peer reviewed and may not be representative of the final product. We included updates of a previously completed CER when the approach to single group studies differed from the original reports.

From each eligible report we only considered “comparative” Key Questions, those that explicitly compare benefits or harms between alternative management strategies. Two reviews pertaining only to diagnostic studies were excluded as they did not evaluate comparative treatment effectiveness.10,11 These two reviews included mostly individuals that had received both diagnostic and reference tests.

Five team members piloted and modified the data extraction form. Thereafter, a single reviewer extracted information from each CER. We collected the following information for each report: title, year of publication, types of interventions compared, whether the authors planned to use single group studies, selection criteria for single group studies (minimum sample size, followup duration, or “other”), whether the results of different single group studies were synthesized separately or together with comparative studies, methods for evidence synthesis (qualitative or quantitative), methods for risk of bias (or quality) and strength of evidence assessment, results of the review regarding single group studies (total number identified, and ratio of single group to total number of studies included), and specific synthesis methods actually utilized in the report. When appropriate, information on the above items was extracted separately for treatment benefits and harms. Whenever possible we extracted the rationale for the methodological approach used. We tabulated summary descriptive statistics across the different reports. The Summary Table of Empirical Review Extractions is presented in Appendix A.

To gain insight into the methodologic issues concerning the use of single group studies in CERs, we convened a panel of experts to help guide this project. The panel members reviewed two drafts of this paper and also provided additional feedback in a teleconference.