# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project:

## Technical Expert Panel

Charles Anello, Sc.D., Sc.M.

Visiting Research Professor

Florida Atlantic University

Founder and Biostatistician

Applied Statistical Concepts, LLC

Wellington, FL

Timothy S. Carey, M.D., M.P.H.

Director, Cecil G. Sheps Center for Health Services Research

Professor of Medicine

University of North Carolina

Chapel Hill, NC

Sander Greenland, Dr.P.H., M.S., M.A.

Professor of Epidemiology

Professor of Statistics

University of California, Los Angeles

Los Angeles, CA

Robert L. Kane, M.D.

Co-Director, Minnesota Evidence-based Practice Center

Minnesota Chair in Long-Term Care and Aging

University of Minnesota

Minneapolis, MN