# Discussion

## Empirical Review

Our review of published CERs to date indicates that although single group studies are very commonly used in CERs, the rationale for including them is not frequently reported. In addition, the methods and approaches to how single group studies are used—either in isolation or integrated with comparative studies—are not clearly defined in the CERs. As an example, several CERs used single group studies to inform the strength of evidence, but the rationale or methodologies were not described. Furthermore, we observed that the terminology used to identify single group studies and their subtypes is not consistent across CERs. For example, single group studies were occasionally identified in CERs using terms that also describe observational studies with an internal concurrent comparison group (e.g., “cohort study,” “observational study”). The lack of consensus on terminology for these designs and their subtypes makes the identification of single group studies in CERs challenging for readers.

It is notable that the majority (19/33, 58%) of the CERs used single group studies in the reporting of harms. Only about half of these CERs (9/19, 47%) described these harms data in the context of data from comparative studies. For those CERs that could not (or did not) juxtapose single group data alongside comparative data, it would be difficult to explore potential causal attributions of the reported harms.

Our empirical evaluation of the use of single group studies among EPCs in their CERs has several limitations. Only a single investigator extracted data from each CER, which could result in misclassification given the subjective nature of some of the elements abstracted. However, we pilot-tested the data extraction form as a group in order to operationalize the process of data abstraction and to promote agreement between readers. A second limitation of the data extraction process was the lack of consistent nomenclature used across EPCs to describe single group studies. This lack of consistent and clear terminology, as well as opacity in reporting on how these studies were used, made our identification of these designs and extraction of information on how they are used challenging. This limitation underscores our recommendation that development of consistent nomenclature for these study designs be prioritized, and that reporting on their use and application be made more transparent. Finally, our empirical review was conducted among the small sample of CERs that had been prepared by EPCs for AHRQ through January 2012 and may not be generalizable to the conduct of comparative evidence reviews in general.

Given ethical and practical constraints to many areas of clinical investigation, it is likely that single group studies will continue to be used to inform CERs, especially in the evaluation of novel technologies or in the examination of harms. Clarity and transparency in the rationale for including or excluding single group studies in CERs should be promoted. As a step forward, we have developed suggestions to improve the reporting of single group studies in CERs (Table 2). We further recommend that a working group across EPCs be convened to develop consistent terminology to identify single group studies, specify circumstances under which single group designs should or should not be included in a CER, discuss how data from single group designs should be considered together with other research designs, and how to incorporate data from single group designs into the deliberation of strength of evidence assessment.

Table 2 Suggestions concerning single group studies reporting in comparative effectiveness reviews

Report clearly in the Methods chapter if single group studies will be included
Report the rationale for including or excluding single group studies
If single group studies are included:; - Report criteria used to select single group studies; - Identify the explicit or implicit comparator (e.g., historical control, implied outcome based on known natural history); - Describe how single group studies are being used in the comparative effectiveness review to address Key Questions; - Describe the methods used to assess quality/risk of bias and strength of evidence

## Considerations When Using Single Group Studies in CERs

A second goal of this report is to illuminate the situations in which single group studies are commonly used in clinical investigation and review the considerations and assumptions required for their appropriate interpretation as a guide for the comparative effectiveness reviewer who encounters this type of evidence. We review these common single group study designs to aid in their interpretation by systematic reviewers and other readers of primary studies.

Although no direct, concurrent comparator is available in single group studies, both explicit and implicit comparisons are frequently made. Explicit comparisons are made when the investigators compare the single group of subjects before and after an intervention, or when the investigators choose to incorporate a historical comparator (e.g., historical data from the research institution or from an external cohort or existing database) in the analysis. Implicit comparisons are made when the expected outcomes in the absence of the intervention of interest are believed to be well known, and the expected effect size from the intervention is large. Depending on the single group study design, observed outcomes in the single treated group could be attributable to the intervention itself, a placebo effect, the natural course of the disease, or confounding by time-varying factors.12 We discuss below these three common single group study designs and the key considerations and assumptions required for their interpretation (summarized in Table 3).

Table 3 Summary of challenges to interpretation of single group study designs

Study Design | Challenge
Before-after comparison of a single group of patients | Changes in factors other than the intervention of interest across the time periods compared are common (e.g., some patients decided to take daily fish oil supplements in the evaluation of newer lipid modifying agents)
Before-after comparison of a single group of patients | Natural recovery may occur (e.g., spontaneous resolution of acute sinusitis)
Before-after comparison of a single group of patients | Subject selection and attrition may be related to disease severity (e.g., some patients with hyperthyroidism dropped out of studies when they become euthyroid)
Comparison to historical control data | Changes in factors other than the intervention of interest across the time periods compared are common (e.g., changes in prevailing societal eating habits in different time periods in the evaluation of treatment for hypertension)
Comparison to historical control data | Information may be unavailable or not reported on the variability of effect estimates from historical control groups
Comparison to historical control data | Inadequate reporting of data sources for historical response rates may occur
Implicit comparison | Unpredictable or variable natural history of disease may occur (e.g., depression)

### Differential (Before-After) Responses in a Single Group

These studies assess the difference in response before and after the administration of an intervention in a single group of patients. Patients serve as their own controls (before the intervention is administered).

The before-after design is commonly used in the evaluation of surgical interventions and other irreversible interventions (treatments or exposures). As an example, the change in blood pressure is assessed in patients with renal artery stenosis before and after vascular surgery (personal communication from K. Uhlig). The generally irreversible nature of the procedure ensures the permanence of the intervention, but the permanence of the intervention alone does not guarantee that observed post-intervention changes are attributable to the procedure.

Time-series analyses represent another example of a before-after single group study design, frequently strengthened with more data points. Time-series analyses follow a given group or region over time, typically without covariate data on individuals. As an example, a time-series study based on employment records merged with prescription records compared work days lost before and after a triptan became available.13 Though time-invariant individual-level confounders do not limit this design, confounding can occur with time-varying factors such as secular trends in incidence rates of disease, clinical care, or cointerventions such as the addition of new services or other quality improvement interventions.

The interpretation of before-after single group studies for the purpose of informing CERs must include consideration of alternative explanations for observed treatment effects. For before-after treatment comparisons, it must be assumed that the intervention of interest presents the only change across the time periods compared if patient status at baseline is to represent what would have happened in the absence of treatment. The influence of adjunctive therapies administered concurrently, or carryover effects from therapies administered before the intervention of interest should be considered. Furthermore, natural recovery, the reduction or disappearance of symptoms regardless of the administration of a given treatment, presents another potential explanation for an observed before-after improvement in a health outcome in a single group comparison. Drawing valid and meaningful inferences about treatment effect using single group observational studies is problematic when evaluating conditions that are fluctuating or intermittent.14 For example, spontaneous resolution of sinusitis is relatively common although antibacterial agents are often prescribed.15 The potential for natural recovery diminishes with increasing disease duration and thus will most significantly affect studies selecting cases that have been recently diagnosed. On the other hand, single group studies of interventions for diseases with stable or steadily progressing courses may be useful.6 For example, individuals with amyotrophic lateral sclerosis steadily decline in function over time, with spontaneous recovery virtually unknown.16,17 A single group study of an intervention for these patients may be able to document meaningful treatment effects.

Single group before-after studies may also be compromised by issues related to subject selection and attrition. Patients selected into a study may represent a relatively extreme subset of the patient population with respect to disease severity and symptoms. For example, due to regression to the mean, a single group study that recruits patients with an incident diagnosis of hypertension may observe an improvement in blood pressure if patients sampled represented relatively severe cases at the baseline time point and there is natural variation in blood pressure over time. Similarly, if symptoms fluctuate over the course of disease, the exacerbation of symptoms may drive patient self-selection into a given study population. In this scenario, treatment effects observed in before-after single group studies may be attributable to the selective sampling of patients at a peak severity in the natural history of disease that have a tendency to return to average severity levels over time regardless of interventions administered. Also, if patients with either more or less favorable outcomes are lost-to-followup, the observed effect of the intervention will be under- or overestimated, respectively. The site of the subject selection may also affect the outcomes of the single group study given patient differences across practice sites. For example, there may be variability in the stage of disease presentation of pathological features among cases recruited from an academic medical center versus community health centers.18 Careful description of the study population is needed to draw meaningful and appropriate inferences.

### Single Group Studies With Explicit Historical Comparisons

Single group studies may report comparative statistical or qualitative analyses comparing results with data obtained from the study with historical data from the research institution or from an external cohort or existing database not drawn from the same institution or population. An example is the comparison of one cohort from one time period that had received one technique for cardiac ablation to abolish atrial fibrillation with another cohort within the same institution from a different time period that had received a different technique.19

Such studies are often used to estimate the impact of systems-level interventions. For example, in an evidence report on the utility of screening bilirubin values for preventing chronic bilirubin encephalopathy,20 three retrospective single group studies were identified that compared rates of phototherapy or readmission for hyperbilirubinemia before and after the implementation of a screening program.21-23 These studies were deemed to be of low methodological quality, but represented the only available evidence on the effect of a systems-level implementation.

The interpretation of these single group studies can be complicated by specific challenges to the validity and precision of historical comparisons. The appropriateness of historical data to represent what would have occurred in the absence of the intervention is limited by patient temporal drift, a systematic, populationwide shift in outcomes that may be attributable to changes in disease staging, imaging, supportive care, evolving therapies, or other concomitant factors.24 Changes in patient populations in newer versus older trials can also invalidate historical comparisons. Differences between the patient populations of a single group trial versus historical control trials can arise due to differences in accrual sites (academic medical center versus community health centers) or changes in patient characteristics such as age, performance status, or other prognostic factors. For example, more recently diagnosed patients may have milder manifestations of a condition due to improved (and therefore likely increased) diagnostic sensitivity. Treatment effects may also be attributable to secular trends in clinical care. For example, a decrease in diabetes-related preventable hospitalizations was observed in the U.S. from 1998 to 2006, possibly indicating improvements in quality of primary care or a higher threshold for hospitalization for individuals with diabetes.25 Using a before-after single group design to evaluate the treatment effect of an antidiabetic agent introduced during this timeframe could be confounded by these examples of temporal drift. In addition, in phase 2 studies the variability of effect estimates from historical control groups is often overlooked and can result in erroneous conclusions regarding the effect of the experimental treatment.26,27 Inadequate reporting of data sources further impedes appropriate interpretation of findings from single group studies with historical comparisons. Roughly half of phase 2 trials did not cite the source of their historical response rates.28

Several simulation studies have been conducted to illuminate the debate concerning the use of single group studies with historical controls versus randomized controlled trial designs in phase 2 studies. One such study concluded that if a small phase 2 study is planned with few patients available, then the single group study is usually adequate, assuming the historical control response rate is well-known.29 Randomized trials were preferred for larger trials and in the setting of high variability in historical response rates.29 A second study used simulations to compare the false positive (α) and false negative (β) rates in single group versus randomized two-arm trial designs in the setting of random and systematic variability in historical control data. This analysis indicated that variability in historical control response rates and changes in patient populations in newer versus older trials affects both false-positive and false-negative error rates in single group studies, but did not impact error rates in the randomized two arm trial designs (though the two arm studies required a 2–4 fold increased sample size).24 A third simulation study compared optimal single group and randomized phase 2 designs with a variety of commonly used false positive (i.e. α = 0.05, 0.10) and false negative (i.e. β= 0.20, 0.10) error rates. The objective of this simulation was to explore which phase 2 design was more likely to correctly identify active treatments so that they could proceed to phase 3 investigations. Simulation data indicated that conducting single group phase 2 studies would lead to a higher proportion of phase 3 trials being conducted using active agents when the true response rate for standard therapy was very low (<5 percent), in the presence of positive historical bias in estimating the null hypothesis (i.e., the estimate of the standard of care treatment effect is greater than the true effect), or when there was no historical bias and low variability in estimates of the historical control rate. On the other hand, randomized phase 2 trials performed better in the presence of a moderately active standard of care agent, and in the presence of negative historical bias (i.e., the estimate of the standard of care treatment effect is less than the true effect).30 This study did not however account for the possibility of a new drug application submission immediately following phase 2.

### Single Group Studies With Implicit Comparisons

Some single group studies do not make explicit comparisons to patient status before treatment or to an assembled historical control group, but rather make implicit comparisons based on knowledge about the natural history of the disease. In these instances, comparisons are extrapolations based on expected outcomes in the “missing” comparison group. Such comparisons are meaningful only when the expected outcomes in the absence of the intervention are well-known, and the expected effect size from the intervention is large. Investigations of anticancer agents for metastatic lung cancer present a useful example. The unlikelihood of spontaneous regression of this disease coupled with relatively impressive response rates as in the case of epidermal growth factor receptor (EGFR) inhibitor treatment of EGFR-mutated lung cancer, single group studies could be informative.31,32 A second example is the use of antibiotics for bacterial meningitis—the natural course of the disease in the absence of antimicrobial therapy is so dramatic, there is little doubt that the beneficial outcomes are attributable to the intervention. However, for some diseases with an apparently uniformly poor prognosis, there may be subtle yet clinically relevant differences between patients who are enrolled in the single group study and those who don't qualify. Careful review of the study population and eligibility criteria is needed to make an assessment concerning external validity. For diseases with an unpredictable or variable natural history, a strong rationale must be available to justify reliance upon implicit comparison groups.

### Single Group Studies and Subgroup Analyses

Subgroup analyses may be applied to single group studies to identify subsets of patients who may be more likely to experience adverse events or favorable health-related outcomes. In these designs, analyses may identify whether a variable is a significant independent predictor of a health outcome or adverse event while taking into account the separate influences of other predictors. However, a single group study cannot quantify treatment effect modification without an accompanying set of strong assumptions, since data on outcomes in the absence of treatment are excluded by design. For example, a single group study of a pharmaceutical agent that enrolls both men and women can estimate the effect of sex on the rate of an outcome of interest. However, evaluating whether the risk of an outcome event differs between men and women under a particular treatment more than it does in the absence of treatment (i.e., whether the relationship between the pharmaceutical agent and the outcome rate is modified by sex), is not possible in the absence of an untreated male group and an untreated female group. In order to estimate whether there is effect modification of treatment effects by sex in single group studies, assumptions would need to be made about the risk of outcome events among both untreated males and females.

### Single Group Studies and Confounding

In the analysis of before-after responses in a single group, confounding by measured or unmeasured factors that are potentially time-varying across the time periods compared remains a critical threat. Statistical methods applied to the analysis of single group studies may be helpful to attempt to adjust for measured confounding factors, or to quantify the potential impact of unmeasured factors on effect estimates. Occupational and environmental studies that include only a single group of exposed individuals attempt to estimate standardized morbidity or mortality ratios by using age-, sex-, and race-specific rates from a general population in place of the unobserved counterfactual rates. The caveat to this approach is that there are likely to be other factors that differ between the exposed group and the reference population that will result in residual confounding of the standardized morbidity or mortality ratio. For time series studies, unmeasured confounders may be addressed by constructing a smooth function of time to serve a proxy for unmeasured confounders. Sensitivity analyses may be useful to generate hypotheses about the strength of an unmeasured confounder, such as a putative secular trend associated with improved outcomes in a before-after study, that would be required to produce an observed given treatment effect if in fact the intervention is not truly associated with any benefit.33