# Conclusions

For many therapeutic strategies, the evidence base includes observational single group studies. Our review of published CERs to date indicates that single group studies are commonly included in EPC reports, especially in reporting of harms. However, the rationale for including these designs is infrequently reported and the methods relevant to their use are not clearly defined. As a step forward, we have developed recommendations to improve the reporting of single group studies. We have also reviewed commonly encountered single group study designs and highlighted the challenges in their interpretation and application to comparative questions as a guide for systematic reviewers.

Understanding the ideal comparison group for the effect of a treatment is essential to the fundamental definition of confounding and drawing causal inferences from all clinical research designs. Indeed, the selection of a comparison group that serves as a good proxy for the counterfactual outcome is a challenge even in analytic observational research designs with direct concurrent comparison groups. Guidance on the interpretation and use of observational research designs in general for CER has been developed.34 Since single group designs are likely to continue to constitute part of the evidence base for certain interventions, it is important that a similar set of recommendations are developed to guide the use of single group studies in CERs.