# Background

Evidence from randomized controlled trials is often unavailable or insufficient to answer all questions posed in a comparative effectiveness review (CER). Thus, following a best-available-evidence approach,1 systematic reviewers often use observational studies including a comparison group to examine the comparative effectiveness and safety of alternative therapeutic strategies. However, there are many instances where even observational studies with a comparison group are unavailable. Therefore, single group studies—those that evaluate a single intervention given to all subjects included in the study design—are often part of the evidence available to systematic reviewers conducting CERs.

We define a single group study as a study that consists of only a single group of subjects included in the study design, in which all subjects received a single intervention and the outcomes are assessed over time (i.e., not a cross-sectional study). These studies may be prospective or retrospective cohort studies. A number of study types would be included in this category, including investigations described as “single arm studies,” case series, registries, “before-after designs,” and time series studies. A classification scheme developed by Campbell and Stanley describes two single group studies consistent with our definition: the “one-shot case study” and the “one-group pretest–post-test design.”2 In the one-shot case study, a single group is studied only once after a treatment is applied. In the one-group pretest–post-test design, a pretest evaluation is followed by a treatment and then a post-test. For the rest of this paper, we will use the simplified term “single group study” when describing these designs in general.

Single group studies are often conducted in the setting of strong therapy preferences (e.g., hyperbaric oxygen therapy for arterial gas embolism3). This is especially true for transplantation studies of vital organs in the setting of rapid and fatal disease progression. For example, in patients with end-stage liver disease, the natural history of disease is so well known that it would be difficult to carry out a trial with an untransplanted study arm. Also, a field of clinical inquiry that is relatively new may not be sufficiently mature to rationalize a comparative hypothesis. For example, novel procedures or drugs are often initially evaluated in single group studies that are used to inform the design of a subsequent study with an internal comparison group.

Single group study designs are commonly used to monitor adverse events that may become evident only with long-term followup of large numbers of treated patients, which is not practical or efficient with other study designs. For example, phase 4 studies to monitor postmarketing adverse events and evaluations of therapies often include a single group of patients managed with the same treatment strategy and followed over time. Open-label extensions of clinical trials present another type of clinical investigation that often lacks an internal, concurrent comparison group. Although they are designed to follow patients for an extended period of time, they also usually evaluate a more highly selected population of patients who completed the randomized trial, tolerated the medication, and agreed to participate in the extension. Expanded access programs (or “compassionate use”) allow the use of an investigational drug outside of a clinical trial to treat a patient with a serious or immediately life-threatening disease or condition lacking satisfactory alternative treatment options. These investigations commonly describe the experience of a single group of patients without a comparison group (for example, see Janne 2004^4^). Finally, registries of patients who have been exposed to a single drug or device may also be assembled for monitoring long-term sequelae without an internal comparison group. An example includes the coordinated effort to study newly introduced devices through the Interagency Registry for Mechanically Assisted Circulatory Support, established to capture detailed clinical data on all patients receiving implantable ventricular assist pumps in the United States.5

Since single group studies do not include a direct, concurrent comparison group, their role in informing comparative effectiveness questions is not straightforward. Observational study designs in general suffer from a potential lack of exchangeability of exposed and unexposed subjects. In other words, the outcome in the untreated group may differ from what would have occurred in the treated in the absence of treatment (the “counterfactual outcome”). The absence of a direct, concurrent untreated comparator in single group studies presents an added challenge to identifying a proxy for the counterfactual, or an answer to the question: “What would have been the treated person's experience if there had been no treatment?” Extrapolations based on the expected outcomes in the “missing” untreated arm are required for inference about treatment effects. In fact, explicit and implicit comparisons are frequently made in single group studies even in the absence of a direct, concurrent comparator. The appropriate interpretation of these implicit and explicit comparisons and their potential utility in CERs must include consideration of the key assumptions underlying each single group design.

The ability of observational studies to answer questions about the benefits or intended effects of pharmacotherapeutic agents, devices, or procedural interventions has been a matter of debate.6 Guidance has been developed for systematic reviewers for decisionmaking on the inclusion of observational studies in general in CERs.6 However, to the best of our knowledge, the use of single group observational studies in CERs has not been specifically addressed in this methods guide or elsewhere. While the value of using single group studies to identify and quantify the occurrence of harms^a^ of interventions is well recognized, the role of these studies in evaluating comparative effectiveness and safety is not well developed. Given that single group studies may comprise a substantial portion of the evidence base for a given clinical question, and in light of the challenges in their interpretation and relevance to questions that are comparative in nature, it is important to clarify whether they are useful in informing comparative effectiveness assessments, and if so, to clarify the assumptions required to support their use.

a Includes adverse events of interventions as well as other harmful events that may be indirectly related to the intervention.

In order to illuminate the use of single group studies in CERs, we conducted an empirical review of current practices in using single group studies in CERs conducted by Evidence-based Practice Centers (EPCs) for the Agency for Healthcare Research and Quality (AHRQ). The summary findings should serve as an impetus for future work in reaching a consensus across EPCs as to when and how single group studies should be used in CERs specifically and systematic reviews in general. In addition to the empirical review, we also provided a narrative review section describing the common single group study designs and the key considerations and assumptions required for their interpretation to help guide comparative effectiveness reviewers who encounter this type of evidence.