# Summary Table of Empirical Review Extractions

CER Name | Year | Pharmaceutical | Surgical | Medical Devices | Behavioral Intervention | Other | Included Single Group Studies for benefit? | Rationale for Inclusion, if Provided | Included Single Group Studies for Harms? | Rationale for Inclusion, if Provided | Total Number of Studies Included | Total Number of Single Group Studies Included | Terms Used
Gastroesophageal Reflux Disease | 2005 | Yes | Yes | Yes | No | No | Yes | To supplement data on long-term effect of surgery | Yes | Not stated | 105 | 23 | Cohort
Epoetin and Darbepoetin for Managing Anemia in Patients Undergoing Cancer Treatment | 2006 | Yes | No | No | No | No | Yes | Used to identify predictors of response to treatment | No | NA | 103 | Not clearly presented | prospective cohort studies
Safety of Analgesics for Osteoarthritis | 2006 | Yes | No | No | No | No | No | NA | Yes | RCT did not provide adequate information | 351 | Not clearly presented | Cohort
Off-Label Use of Atypical Antipsychotics | 2007 | Yes | No | No | No | No | No | NA | No | NA | 84 | NA | NA
Second-Generation Antidepressants in the Pharmacologic Treatment of Adult Depression | 2007 | Yes | No | No | No | No | No | NA | Yes | Not stated | 200 | Not clearly presented | Cohort study
Oral Diabetes Medications for Adults With Type 2 Diabetes | 2007 | Yes | No | No | No | No | No | NA | Yes | Not stated | 216 | Not clearly presented | Single group studies not explicitly called out
Comparative Effectiveness of Percutaneous Coronary Interventions and Coronary Artery Bypass Grafting for Coronary Artery Disease | 2007 | No | Yes | No | No | No | No | NA | No | NA | 113 | NA | NA
ACEIs and ARBs for Treating Essential Hypertension | 2007 | Yes | No | No | No | No | No | NA | No | NA | 69 | NA | NA
Drug Therapies for Rheumatoid or Psoriatic Arthritis | 2007 | Yes | No | No | No | No | Yes | Not stated | Yes | Not stated | 156 | Not clearly presented
Treatments To Prevent Fractures in Men and Women With Low Bone Density or Osteoporosis | 2007 | Yes | No | No | Yes | No | No | NA | Yes | Not stated | 566 | 31 | Single group studies not explicitly called out
Therapies for Clinically Localized Prostate Cancer | 2008 | Yes | Yes | Yes | No | No | Yes | Few trials | Yes | Not stated | 436 | 352 | National data bases
Insulin Analogues in Premixed Formulations for Adults with Type 2 Diabetes | 2008 | Yes | No | No | No | No | No | NA | No | NA | 45 | NA | NA
Radiofrequency Catheter Ablation for Atrial Fibrillation | 2008 | Yes | No | Yes | No | No | No | NA | Yes | Not stated | 120 | 100 | Single group studies not explicitly called out
Lipid-Modifying Agents | 2009 | Yes | No | No | No | No | No | NA | No | NA | 135 | NA | NA
Medications To Reduce Risk of Primary Breast Cancer in Women | 2009 | Yes | No | No | No | No | No | NA | No | NA | 123 | NA | NA
ACEIs and ARBs Added to Standard Medical Therapy for Treating Stable Ischemic Heart Disease | 2009 | Yes | No | No | No | No | No | NA | No | NA | 61 | NA | NA
Radiotherapy Treatments for Head and Neck Cancer | 2010 | No | No | No | No | Radiotherapy | Yes | Used single arm studies for hypothesis generation | Yes | Used single arm studies for hypothesis generation | 108 | 70 | Single arm studies
In-Hospital Use of Recombinant Factor VIIa for Off-Label Indications vs. Usual Care | 2010 | Yes | No | No | No | No | No | NA | Yes | Rare harms | 74 | 19 | Noncomparative observational studies
Nonoperative and Operative Treatments for Rotator Cuff Tears | 2010 | Yes | Yes | No | Yes | Acupuncture | Yes | Not stated | Yes | Not stated | 137 | 71 | Single group studies not explicitly called out
Recombinant Human Growth Hormone in the Treatment of Patients With Cystic Fibrosis | 2010 | Yes | No | No | No | No | Yes | Not stated | Yes | Not stated | 26 | 8 | Single group studies not explicitly called out
Screening and Treatment of Subclinical Hypothyroidism or Hyperthyroidism | 2011 | Yes | No | No | No | No | No | NA | Yes | Not stated | 8 | 2 | Single group studies not explicitly called out
Traumatic Brain Injury and Depression | 2011 | Yes | No | No | Yes | Yes | Yes | Not stated | No | NA | 2 | 1 | Single group studies not explicitly called out
Therapies for Children With Autism Spectrum Disorders | 2011 | Yes | No | No | Yes | No | Yes | Lack of studies with comparison groups | Yes | Lack of studies with comparison groups | 183 | 74 | Studies without a comparison group; prospective case series; single crossover trial; single arm studies
DMARDs in Children With Juvenile Idiopathic Arthritis | 2011 | Yes | No | No | No | No | No | NA | Yes | To identify AEs that were not reported by other study designs | 198 | Not clearly presented | Case reports; Case series
Pain Management Interventions for Hip Fracture | 2011 | Yes | No | No | No | No | No | NA | No | NA | 83 | NA | NA
Early Diagnosis, Prevention, and Treatment of Clostridium difficile Infection | 2011 | Yes | No | No | No | No | No | NA | No | NA | 29 | NA | NA
Diagnosis and Treatment of Obstructive Sleep Apnea in Adults | 2011 | Yes | Yes | Yes | Yes | Yes | No | NA | Yes | Dearth of comparative surgical data | 190 | 13 | Noncomparative cohort studies
Nonpharmacologic Interventions for Treatment-Resistant Depression in Adults | 2011 | Yes | No | Yes | Yes | Yes | No | NA | No | NA | 79 | NA | NA
Terbutaline Pump for the Prevention of Preterm Birth | 2011 | Yes | No | Yes | No | No | No | NA | Yes | Limited availability of RCTs | 15 | 2 | Noncomparative studies; Observational studies
Antiepileptic Medications in Patients With Epilepsy | 2011 | Yes | No | No | No | No | Yes | Not stated | Yes | Not stated | 68 | 9 | Single group studies not explicitly called out
Adjunctive Devices for Patients With Acute Coronary Syndrome | 2011 | No | No | Yes | No | No | No | NA | No | NA | 175 | NA | NA
Off-Label Use of Atypical Antipsychotics – Update | 2011 | Yes | No | No | No | No | Yes | Limited availability of RCTs | Yes | Limited availability of RCTs | 331 | Not clearly presented | Case series; Open label; Chart review; Open label pilot study; Self-controlled case series
ADHD: Effectiveness of Treatment in At-Risk Preschoolers | 2011 | Yes | No | No | Yes | No | No | NA | No | NA | 129 | NA | NA