# Acronyms

AHRQ: Agency for Healthcare Research and Quality
CER: Comparative Effectiveness Review
EGFR: Epidermal Growth Factor Receptor
EHC: Effective Health Care
EPC: Evidence-based Practice Center