# Results

## Demographic Information of Peer Reviewers

As a whole, the group of people available to conduct and review search strategies in the EHC Program is professionally educated and very experienced. Of the 24 respondents to the demographic survey, 20 (83 percent) have master’s degrees in library science. Most have more than 10 years’ experience as a librarian or other information professional. Sixty-seven percent of respondents have more than 5 years experience contributing to systematic reviews, with 63 percent having contributed to more than 10 systematic reviews. These experienced searchers have a variety of relationships with the EPCs for whom they do searches. Although 33 percent are full time EPC team members, another 38 percent have appointments to other institutional units and perform searches on an as-needed basis (see Table 1). This variety can be seen in the various titles the searchers hold: Assistant EPC director; Program Director; Associate Director for Public Services (2); Research Librarian (2); Senior Information Specialist (2); Research Associate (3); Electronic Services Librarian; Head, Reference Services; Program Manager, Medical Information and Coding Services; Information Specialist; Library Director; Acting Associate Director for Information Services; Hotline Response Team Leader; Senior RA; Hotline Information Specialist; Program Support Assistant; Librarian; Director, HTA/EPC Information Center; Library and Information Technician; and Associate Director.

Table 1 Demographic information from peer reviewers

Do you have a Master of Library Science degree?
Yes 83% (20) | | | No 17% (4)
How many years of experience do you have as a librarian or other information professional?
<5 8% (2) | | 5–10 38% (9) | | >10 54% (13)
Approximately how many years of experience do you have contributing to systematic reviews?
<5 33% (8) | | 5–10 50% (12) | | >10 17% (4)
To approximately how many systematic reviews have you contributed in the past?
<5 25% (6) | | 5–10 13% (3) | | >10 63% (15)
What is your employment status with your Evidence-based Practice Center (EPC)?
Full-Time | Part-Time | Contractor to the EPC | As needed for searching | Other
33% (8) | 17% (4) | 4% (1) | 38% (9) | 8% (2)

## Review Process Questionnaires

Of the 25 peer reviewers invited to participate, 24 completed the initial free-form round of reviews, and 15 completed either the PRESS review or a second free-form review as part of our control group. Although it is not clear why respondents failed to complete all reviews, it may be related to the reviewers’ relationship to the EPC they work for, as only one of the reviewers lost to followup reported having a full-time appointment to their EPC.

For the most part peer reviewers were positive about the review process, although many hesitated to incorporate the review process into their current workflow. Although 91 percent of reviews using the PRESS instrument took less than 2 hours to complete, compared with only 54 percent of the first round free form reviews, this difference was no longer present for the second free form reviews which were all completed within this time frame. Only a minority of respondents reported that they could incorporate peer review into their workflow or that they would be willing to take on peer review duties on a more permanent basis, the comments associated with these answers indicate that most participants cite time as the primary barrier to being able to take on peer review duties or incorporate these into their workflow (see Table 2).

Table 2 Time taken for reviews and willingness to review in the future

| First Round Free Form Reviews N=24 | PRESS Reviews N=11 | Control Reviews (second Free Form Review only) N=4
Time to complete review
< 2 hours | 54% (13) | 91% (10) | 100% (4)
> 2 hours | 46% (11) | 9%(1) | 0% (0)
Could this be incorporated into your workflow?
Yes | 42% (10) | 46% (5) | 25% (1)
No | 8% (2) | 9% (1) | 0% (0)
Maybe | 50% (12) | 46% (5) | 75% (3)
Would you be willing to take on peer review duties on a more permanent basis?
Yes | 29% (7) | 37% (4) | 25% (1)
No | 21% (5) | 27% (3) | 0% (0)
Maybe | 50% (12) | 37% (4) | 75% (3)

All of the reviewers found the background material (systematic review protocol) helpful to the review. While reviewing the search strategies, reviewers did more than simply read the search strategy and accompanying protocol. Many reviewers in all groups performed additional activities to inform their comments. Such activities included running live searches, checking on documentation, and reviewing controlled vocabulary. The reviewers using the PRESS instrument performed slightly fewer of these auxiliary activities (See Table 3).

Table 3 Usefulness of background material and auxiliary activities performed

| First Round Free Form Reviews N=24 | PRESS Reviews N=11 | Control Reviews (second Free Form Review only) N=4
Usefulness of background material (protocol)
Helpful | 96% (23) | 100% (11) | 100% (4)
Neutral | 4%(1) | 0% (0) | 0% (0)
Unhelpful | 0% (0) | 0% (0) | 0% (0)
Additional activities undertaking during review process
Run live searches in database | 92% (22) | 64% (7) | 75% (3)
Consult documentation for database to check syntax, etc. | 62% (15) | 46% (5) | 75% (3)
Consult a database’s thesaurus | 75% (18) | 82% (9) | 50% (2)

Of those who used the PRESS instrument, 82 percent (9) indicated that the instrument was helpful, 18 percent (2) reported that it was neither helpful nor limiting, and none of the reviewers indicated that the PRESS instrument was limiting. Twenty seven percent (3) of respondents said that they preferred the PRESS instrument and being required to use it, while 54 percent (6) indicated that they prefer having the checklist but not being required to use it; 18 percent (2) indicated that they prefer not having the checklist at all.

## Review Content

The PRESS instrument reviews contained more recommendations on the whole and in particular had more comments that could be termed error detection—specific comments about spelling or syntax indicating that a mistake had been made. Other comments can be grouped into suggestions to increase sensitivity (recall), recommendations intended to increase specificity (precision), and recommendations about reporting the search strategy and other issues. The results of the control were similar to the other free form reviews in their lack of error detection and relative brevity. Therefore, it is likely that use of the PRESS instrument prompts both more comments and the identification of specific errors in the search strategy. At the same time, many of the reviewers were careful to point out that their suggestions were just that, suggestions; they were unsure if these would either change or improve the search results. Specific types of comments made by each type of reviewer are listed in Table 4 below.

Table 4 Content of reviews

| First Round Free Form Reviews N=24 | PRESS Reviews N=11 | Control Reviews (second Free Form Review only) N=4
Recommendations to increase sensitivity | - Additional terms suggested; - Suggestions to search for observational studies (or to not limit to RCTs); - Use of plurals and truncation; - Use of proprietary or brand names; - Locating non-indexed citations in Pubmed | - Additional terms suggested; - Suggestions to search for observational studies (or to not limit to RCTs); - Use of plurals and truncation; - Use of proprietary or brand names; - Additional concepts suggested; - Use of device names; - Additional pharmacological action terms suggested | - Additional terms suggested; - Suggestions to search for observational studies (or to not limit to RCTs); - Use of proprietary or brand names
Recommendations to increase specificity | - Use of filters suggested; - Use of publication type as a limiter; - Use of human limits; - Using sex limits; - Use of field searching; - Use of MeSH major headings; - Use of subheadings | - Use of filters suggested; - Use of publication type as a limiter; - Use of human limits; - Use of sex limits | - Use of publication type as a limiter; - Use of human limits; - Narrower MeSH terms suggested; - Use of abbreviations that could bring false hits
Errors detected | None | - Errors in use of parentheses; - Spelling errors identified; - Error in phrase searching; - Errors in use of Boolean operator | None
Other issues | - Previous indexing terms; - English language limits (conflicting recommendations); - Database selection | - Whether or not to search for specifically named outcomes or comparators; - Apparent lack of use of controlled vocabulary | None
Recommendations about reporting | - Identification of unnecessary explosions; - General comments on “readability” of search strategies | - Identification of unnecessary explosions; - General comments on “readability” of search strategies | - General comments on “readability” of search strategies

## Original Searchers Response

In 97 percent of cases, the original searcher indicated that the comments did not cause them to alter their search strategies. However, it should be noted that only one original searcher indicated that this was because he or she disagreed with the review. In nearly all other cases, the reason given was simply that the report had already gone forward, and it would be too late to incorporate any changes suggested. Original searchers were also asked to comment on the content of the reviews. The responses to reviewers indicate that there are a number of areas where there is no commonly understood “correct” approach. In particular, the following issues seem to be unresolved in that multiple reviews on a search strategy offered conflicting suggestions or the original searcher had specific responses as to why his or her approach differed from a reviewer’s suggestion:

- Whether or not to specifically search on outcomes
- The usefulness of limits (humans, language, age, and sex)
- Whether or not additional search terms yield additional results or additional relevant results
- Which fields are most useful when using fielded searching
- The use of inclusion and exclusion criteria as a complement to search strategies