# References

1 Effective Health Care Program. http://www.effectivehealthcare.ahrq.gov/index.cfm. Accessed November 14, 2011.
2 Relevo R, Balshem H. Finding evidence for comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1168-77. [pmid: 21684115].
3 Ford AC, Guyatt GH, Talley NJ, Moayyedi P. Errors in the conduct of systematic reviews of pharmacological interventions for irritable bowel syndrome. American Journal of Gastroenterology. Feb. 2010;105(2):280-8. [pmid: 19920807].
4 Sampson M, McGowan J. Errors in search strategies were identified by type and frequency. Journal of Clinical Epidemiology. 2006;59(10):1057-63. [pmid: 16980145].
5 Golder S, Loke Y, McIntosh HM. Poor reporting and inadequate searches were apparent in systematic reviews of adverse effects. Journal of Clinical Epidemiology. May. 2008;61(5):440-8. [pmid: 18394536].
6 Roundtree AK, Kallen MA, Lopez-Olivo MA, Kimmel B, Skidmore B, Ortiz Z, et al. Poor reporting of search strategy and conflict of interest in over 250 narrative and systematic reviews of two biologic agents in arthritis: A systematic review. Journal of Clinical Epidemiology. Nov. 13. 2008;62(2):128-37. [pmid: 19013763].
7 Yoshii A, Plaut DA, McGraw KA, Anderson MJ, Wellik KE. Analysis of the reporting of search strategies in Cochrane systematic reviews. J Med Libr Assoc. Jan. 2009;97(1):21-9. [pmid: 19158999].
8 Demicheli V, Di Pietrantonj C. Peer review for improving the quality of grant applications. Cochrane Database Syst Rev. 2007;(2):MR000003. [pmid: 17443627].
9 Jefferson T, Rudin M, Brodney Folse S, Davidoff F. Editorial peer review for improving the quality of reports of biomedical studies. Cochrane Database Syst Rev. 2007;(2):MR000016. [pmid: 17443635].
10 Institute of Medicine. Committee on Standards for Systematic Reviews of Comparative Effectiveness R, Eden J Finding what works in health care : standards for systematic reviews. Washington, D.C. National Academies Press. 2011.
11 Velasco M, Perleth M, Drummond M, Gurtner F, Jorgensen T, Jovell A, et al. Best practice in undertaking and reporting health technology assessments. Working group 4 report. Int J Technol Assess Health Care. Spring. 2002;18(2):361-422. [pmid: 12053427].
12 National Institute for Health and Clinical Excellence. The guidelines manual 2009. http://www.nice.org.uk/guidelinesmanual. Accessed November 14, 2011.
13 Kristensen F, Sigmund H, editors. Health Technology Assessment Handbook. Copenhagen. Danish Centre for Health Technology Assessment, National Board of Health. 2007.
14 Institute for Quality and Efficiency in Health Care. General Methods. 2008.
15 Higgins JPT, Green S, Cochrane C. Cochrane handbook for systematic reviews of interventions. Chichester, England; Hoboken, NJ. Wiley-Blackwell. 2008.
16 Akers J. University of York Centre for Reviews and Dissemination. Systematic reviews : CRD’s guidance for undertaking reviews in health care. [York]. Centre for Reviews and Dissemination. 2009. http://www.york.ac.uk/inst/crd/SysRev/!SSL!/WebHelp/SysRev3.htm.
17 Sampson M, McGowan J, Lefebvre C, Moher D, Grimshaw JM. PRESS: Peer Review of Electronic Search Strategies. Ottowa. Canadian Agency for Drugs and Technologies in Health. 2008.
18 Sampson M, McGowan J, Cogo E, Grimshaw J, Moher D, Lefebvre C. An evidence-based practice guideline for the peer review of electronic search strategies. Journal of Clinical Epidemiology. 2009. Feb. 18. [pmid: 19230612].
19 Crumley E, Bhatnagar N, Stobart K. Peer reviewing comprehensive search strategies in hemophilia and von Willebrand disease. J Can Health Lib Assoc. 2004;25(4):113-6.
20 Haahr M. Random.org. 2011. November 28, 2011. www.random.org.
21 Canadian Health Libraries Association 2011 Conference, 26–30 May 2011 Calgary, Alberta, Canada: Poster abstracts/Association des bibliothèques de la santé du Canada Congrès 2011, 26 au 30 mai 2011 Calgary (Alberta), Canada: Resumes d’affiches. Journal of the Canadian Health Libraries Association. 08. 01. 2011;32(2):91-100.
22 McGowan J, Sampson M, Lefebvre C. An Evidence Based Checklist for the Peer Review of Electronic Search Strategies (PRESS EBC). 2010.
23 Sampson M, McGowan J, Tetzlaff J, Cogo E, Moher D. No consensus exists on search reporting methods for systematic reviews. Journal of Clinical Epidemiology. [Research Support, N.I.H., Extramural Research Support, Non-U.S. Gov’t]. Aug. 2008;61(8):748-54. [pmid: 18586178].
24 Craven J, Levay P. Recording Database Searches for Systematic Reviews - What is the Value of Adding a Narrative to Peer-Review Checklists?. A Case Study of NICE Interventional Procedures Guidance. 2011.
25 Niederstadt C, Droste S. Reporting and presenting information retrieval processes: the need for optimizing common practice in health technology assessment. Int J Technol Assess Health Care. Oct. 2010;26(4):450-7. [pmid: 20942989].