# Methods

Search strategies were identified at the research protocol phase on the EHC Web site(1). Search strategies posted at the research protocol phase were chosen because they are publicly available on the EHC Web site, contain background materials needed to evaluate the search strategies (e.g., key question, analytic framework), and represent the stage of the systematic review process at which reviewing and changing a search strategy is most likely to be accommodated. Intervention either prior or after this point is impractical; on one hand, final search strategies are not publically available prior to the posting of the research protocol, and on the other, waiting until a comparative effectiveness review draft report is posted is likely too late in the process to change search strategies and literature retrieval.

Five search strategies were selected from posted pharmacological treatment research protocols on the EHC Web site in July 2011. Pharmacological treatment topics were chosen because they represent the most common type of comparative effectiveness review published by the EHC Program. The reports selected were:

- Effectiveness of Epoetin and Darbepoetin for Managing Anemia in Patients Undergoing Cancer Treatment
- Comparative Effectiveness of Treatment for Glaucoma
- Comparative Effectiveness of Treatments for Phenylketonuria
- Comparative Effectiveness of Pharmacologic Therapies for the Management of Crohn’s Disease
- Comparative Effectiveness of Treatment of Women with Coronary Artery Disease (CAD)

Once the reports were selected, the EHC Evidence-based Practice Centers (EPCs) responsible for each of them was contacted to identify the original expert searcher who had developed the search strategy. The searchers were recruited to respond to the reviews of their search strategies and to indicate whether the reviews would have likely changed the search strategies. All five original expert searchers agreed to participate.

All 14 EPCs were contacted to identify individuals who regularly conduct literature searches within each center. Twelve centers responded, identifying 39 eligible individuals, of whom 25 agreed to participate as peer reviewers. Because of the relatively small pool or participants we wanted to use all reviewers to review a search strategy both with and without the PRESS instrument, so that the variation seen could not simply be attributed to differing styles of the reviewers. Once a reviewer uses the PRESS instrument, subsequent reviews could not truly be considered free form, a simple cross-over design was not possible. Instead, a small group of reviewers (N=5), were preserved as a control group, in order to discern changes in reviews due to the use of the PRESS instrument from changes in reviews due simply to the reviewer having more experience reviewing. These control reviewers simply reviewed both of their search strategies without using the PRESS instrument. The 25 peer reviewers were randomly divided into these two groups using Random.org20. The five reports, used across both the experimental and control groups, were randomized within each group of reviewers, using www.Random.org 20 (See Figure 1).

Figure 1 Flow diagram for study participants

Figure one is a flow diagram of the study participants. There were 39 eligible participants, of which 25 were enrolled. Of the 25 enrolled participants, 20 were randomized to the PRESS group and 5 were randomized to the control group. All participants (in both groups) were asked to complete the demographic questionnaire. Because one participant was lost to follow-up only 24 completed this survey. The same group of participants all completed a “free form” review on a randomly selected search strategy. Following this review, those assigned to the PRESS group completed a practice review, and subsequently a review on a randomly selected search strategy using the PRESS instrument. Nine participants were lost to follow-up leaving 11 participants who completed the PRESS review. Those assigned to the control group completed zero reviews with the PRESS instrument and instead completed a second “free form” review on a randomly selected search strategy. A total of four participants completed the second review.

Peer reviewers and original expert searchers were required to complete one demographic information form at the beginning of the project, and for each review they completed a review form and process questionnaire. All forms for the research project were created and administered online using Survey Monkey. The demographic information survey was completed to gain more information about the project participants within the EHC Program (peer reviewers who were also original expert searchers only completed the demographic information survey once). Demographic form questions included (see Appendix A for complete survey):

- What is your position title?
- Do you have a Master of Library Science degree (M.L.S., M.L.I.S., M.A.-L.I.S., etc.)?
- How many years of experience do you have as a librarian or other information professional?
- Approximately how many years of experience do you have contributing to systematic reviews?
- Approximately how many systematic reviews have you contributed to in the past?
- What is your employment status with your Evidence-based Practice Center (EPC)?

Both experimental and control peer reviewer groups were then asked to write a free form review with these guiding instructions:

“Please indicate the title of the Brief/Report/Review whose search strategy you are reviewing and then complete your review of it. It would be most helpful when you identify an issue(s) with the search strategy that you indicate:

- List any errors or changes you would want to make in the search strategy.
- Whether you consider it a conceptual or technical error.
- Describe any changes you would make to the search strategy.”

After completing the initial free form review, all reviewers were asked to complete a process questionnaire, which included the following questions (see Appendix B for the complete questionnaire):

- How long did it take you to complete your review?
- How helpful was the background material provided with the search strategy?
- During the peer review process, did you do any of the following (please check all that apply): (Run live searches in databases; Consult documentation for a database to check syntax, etc.; Consult a database’s thesaurus; Other)
- Considering the time and effort needed to review the search strategy, is this something that could be incorporated into your workflow?
- Would you be willing to take on peer review duties on a more permanent basis?

After each peer reviewer submitted the first free form review, the second set of reports was sent out to the reviewers. Each of the five reviewers in the control group was assigned a second randomly selected report search strategy to review and was given the same free form review instructions and online forms (review and process questionnaire) as above. Once these reviewers submitted the second free form review and process questionnaire their participation was complete.

The participants in the experimental group were all given the same report as a training exercise in using the PRESS instrument. This training exercise allowed them to practice with the new review format and seek guidance on any questions. The search strategy from the Screening and Treatment of Subclinical Hypothyroidism or Hyperthyroidism report was used for the training exercise. No content analysis was performed on these reviews. The experimental group filled out the PRESS instrument review form, which included the following PRESS instrument specific questions (see Appendix C for the complete form):

- Translation: Is the search question translated well into search concepts?
- Operators: Are there any mistakes in the use of Boolean or proximity operators?
- Subject headings: Are any important subject headings missing or have any irrelevant ones been included?
- Natural language: Are any natural language terms or spelling variants missing, or have any irrelevant ones been included? Is truncation used optimally?
- Spelling & syntax: Does the search strategy have any spelling mistakes, system syntax errors, or wrong line numbers?
- Limits: Do any of the limits used seem unwarranted or are any potentially helpful limits missing?
- Adapted for database: Has the search strategy been adapted for each database to be searched?

The process questionnaire that peer reviewers completed after their reviews included extra questions on the PRESS instrument in addition to the process questions used for the free form review:

- Did the PRESS Checklist help you to prepare your review?
- Do you prefer to formulate your review however you wish or have guidance in the form of a checklist or something similar?

After completing the training review, each peer reviewer from the experimental group received his/her last report search strategy to review and completed the same PRESS instrument review form and process questionnaire as in the training exercise. A content analysis was performed on the contents of these reviews.

Finally, original expert searchers were sent all of the reviews of their search strategies and asked to complete an online form for each review, answering the following questions (see Appendix D for the complete form):

- Did the review comments cause you to alter your search strategy?
- Do you have any responses to specific review comments?
- If you edited your search strategy, did you (please check all that apply):
  ○ Change search concepts
  ○ Change Boolean operators
  ○ Add/delete subject terms
  ○ Add/delete natural language terms
  ○ Correct a misspelling
  ○ Add/delete spelling variants (e.g. randomized/randomized)
  ○ Correct truncation
  ○ Correct system syntax errors
  ○ Correct wrong line number
  ○ Add/delete limits
- Do you think peer review of search strategies should be incorporated as standard practice for systematic reviews?
- Regardless of whether or not the review comments changed this search, does having the search peer reviewed increase your confidence in the quality of the search?
- Thinking about all of the reviews you received, which format was the most useful (free-form or PRESS Instrument)? (Note: you need only answer this question once, after you have read and commented on all of the reviews.)