# Introduction

Systematic reviews are distinguished from other types of reviews by the process by which they are conducted. In the attempt to arrive at and present a comprehensive, unbiased view of the available evidence, systematic reviewers seek to follow methodological guidance for each step in the systematic review process to the extent permitted by the needs of their specific review. In common with other groups that routinely fund or produce systematic reviews, the Agency for Healthcare Research and Quality (AHRQ) Effective Health Care (EHC) Program has developed such guidance1. In nearly all steps of the review process, group consensus (e.g., topic development, selection criteria development), dual reviewers (e.g., title and abstract review, quality rating, data abstraction) or peer review (e.g., manuscript development) are employed. By not relying on a single individual, peer review and other group processes intend to reduce bias and improve quality.

In contrast, current guidance within the EHC Program does not specify group consensus, dual review, or peer review of the search strategies for bibliographic databases2. Because the search strategy forms the foundation of a systematic review, it is important that it be unbiased and of high quality. And yet, studies of published systematic reviews show that search strategies often contain errors or are sub-optimal in terms of recall and precision3,4, although quality assessment of search strategies is often hampered by poor reporting5–7. Peer review is widely regarded as an appropriate mechanism for improving the quality of other scientific endeavors such as reports of biomedical studies and grand applications, although evidence of the effectiveness of this process is mixed8,9. Peer review of search strategies could be a way to improve the quality of the search and thereby the systematic review it supports.

With the exception of the current guidance on standards for systematic reviews from the Institute of Medicine (IOM) which requires independent peer review of search strategies10, most methodological guidance for systematic reviews does not mention peer review of search strategies. This includes guidance developed for the European Collaboration for Health Technology Assessment (ECHTA)11, National Institute for Health and Clinical Excellence (NICE)12, Danish Centre for Health Technology Assessment (DECEHTA)13, Institute for Quality and Efficiency in Healthcare (IQWiG)14, and The Cochrane Handbook15. The University of York Centre for Review and Dissemination systematic review methodology16 suggests peer review of search strategies but does not require it.

To address this issue, the Canadian Agency for Drugs and Technology in Health (CADTH) and the Cochrane Information Retrieval Methods Work Group have developed the Peer Review of Electronic Search Strategies (PRESS) instrument17,18. The developers of PRESS first conducted a systematic review to identify evidence related to quality issues and errors in complex electronic search strategies17,18. The review identified elements important to complex search strategies. These elements were then sent to a group of expert searchers who were asked to identify any additional elements and assess the importance of the previously identified elements. These elements were combined to produce the PRESS instrument, which was subsequently checked for validity with peer review forums of expert searchers. The resulting PRESS checklist contains the following elements:

- Conceptualization of research question
- Spelling errors and wrong line numbers
- Translation of search strategy to different databases
- Missed subject headings
- Missed natural language search terms
- Spelling variants and truncation
- Irrelevant subject headings
- Irrelevant natural language terms
- Search limits

While peer review has the potential to improve search strategies,19 it is not clear how much it would change the EPC reports conducted by the EHC Program. Additionally, the costs associated with the implementation of a peer review process are unknown. In order to investigate peer review of search strategies within the context of the EHC Program, we implemented a peer review pilot to both test the process and determine if the PRESS instrument is a useful tool for such review. Expert searchers from within the program were first asked to review a search strategy from a current EHC report without the PRESS instrument and then asked to review a different search strategy using the PRESS instrument. After each review they were asked about the process of the review. The authors of the original searches were shown the reviews and asked if the reviews would have changed their search strategies. Finally, the content of all reviews was analyzed.

Specifically, we investigated whether peer review has the potential to change search strategies (are reviews useful and will they be used?), measured the harms of the intervention (how much time does it take for peer review? How will this affect the systematic review timeline?), and compared the use of the PRESS instrument with “free form” reviews (in terms of time required to write the review and the type of comments). This study investigated only the resources needed for peer review, the preferences of participants, and the potential impact on the search strategy. It did not attempt to measure actual differences between peer reviewed and non-peer reviewed search strategies, or what effect this would have on the conclusions of a systematic review. If peer review has the potential to affect search strategies, further research will be needed to investigate whether peer review might change search results and the conclusions of a systematic review.

The objectives of the current study were:

1. To determine if peer review changes search strategies
2. To discover the time burden for peer review, and
3. To examine whether use of the PRESS instrument would improve review processes.