# Discussion

## Objective 1: Does peer review change search strategies?

The original searchers overwhelmingly said that the content of the reviews did not change the search strategy. However, this is likely due to timing rather than the actual content of the reviews, as most of the original reviewers clearly indicated that they did not change search strategies because of the timing and not the content of the reviews. It may be that even at the protocol stage, the actual progress of the systematic review is too far along for peer review of search strategies to be helpful. However, reviews with the PRESS instrument did identify errors in search strings.

## Objective 2: What is the time burden for peer review?

Most reviews were completed in less than two hours. Although across all three groups, between 37 percent and 75 percent of reviewers felt ambivalent about whether they would be willing to take this on as a permanent duty, more respondents responded yes than no regardless of whether or not the PRESS instrument was used. The comments of the original searchers also suggest that if search strategies are to be reviewed, it needs to be done early in the review process in order to avoid delaying the entire report. Most of the comments from the original searchers indicated that by the time they received the reviews of the search strategies the reports were either at or near completion and it would be too late to adjust the search strategy. While it was convenient for this pilot project to use publically posted protocols, in order for peer review to be useful it needs to be performed earlier in the systematic review process, likely before the protocol is posted publically.

## Objective 3: Compare PRESS instrument to free form evaluations

The PRESS instrument is preferred by the reviewers, although some would still prefer for the checklist to be optional. The reviews using the PRESS instrument take less time than free form reviews and yield more content, but it is also likely that experience reviewing multiple search strategies also results in greater efficiency when reviewing. The PRESS instrument does seem to be superior to free form evaluations in that only with the PRESS instrument were actual errors in searches found.