# Appendixes

Appendix A Demographic Questionnaire

Appendix B Free-Form Review Form

Appendix C PRESS Review Form

Appendix D Questionnaire for Original Searchers