# Results

The first part of the Results section covers proportions, and the second part covers rates. For parsimony, and after careful examination of all scenarios, we decided to describe in detail findings on a representative subset of the performed analyses.^h^ We start with comparisons and recommendations across all methods, and proceed to provide more details on pairwise comparisons between approximate methods and between approximate and discrete likelihood methods. Finally, results on rates were very similar to those from proportions. Thus, we report in detail results in proportions, and provide a succinct summary of the results on rates. We conclude with practical recommendations for applied meta-analysis.

h We report simulation scenarios corresponding to the combinations of the [underlined: underlined] values in Table 2 for proportions, and Table 3 for rates.

1. Results for Proportions: Results for meta-analysis of proportions:
  a. Overview of Results Across All Methods: Overview of results from comparisons across all methods.
  b. Simulation results for random effects meta-analysis:
    i. Pairwise Comparisons Among Approximate Methods—Random Effects Meta-Analysis: Comparisons between the three approximate methods (untransformed, canonical and variance stabilizing transformation)
    ii. Pairwise Comparisons Between Approximate and Discrete Likelihood Methods for Random Effects Meta-Analysis: Comparisons between approximate versus discrete likelihood methods
  c. Comparison Between Fixed and Random-Effects Discrete Likelihood Binomial Methods: Simulation results on the comparison of fixed versus random effects meta-analysis for the discrete likelihood methods
2. Results for Rates: Results for meta-analysis of rates.
  a. Overview of Results Across All Methods: Overview of results from comparisons across all methods.
3. Practical Recommendations for Meta-Analysis of Proportions or Rates: Practical recommendations for meta-analysis.

Observations from simulations are listed as bullet points. An explanation is provided in a grey box after each observation:

- [An observation on the proportion bias, proportion RMSE or coverage probability of a meta-analysis method/strategy.]

[An explanation for the observation]

## Results for Proportions

### Overview of Results Across All Methods

Table 6 shows the proportion bias with the random effects analysis methods for selected scenarios with high heterogeneity. Table 7 is the corresponding table for RMSE, and Table 8 for coverage. In the Appendix we present results for the corresponding scenarios with zero heterogeneity. We also conducted sensitivity analyses where the back-transformations of the meta-analysis point estimates were done with numerical integration instead of a simple back-transformation (see Methods section under Approximate Methods). The results of the sensitivity analyses were similar to the main analyses and are not shown.

Table 6 Comparison of proportion bias across random effects methods (selected scenarios with high heterogeneity)

Scenario | K | Proportion | Sample size | Exp count | Approximate untransformed | Approximate logit | Approximate arcsine | Discrete (fraction converged) | Discrete (random) | Discrete (hybrid)
S1 | 5 | 0.001 | small | <0.1 | 12.380 | 14.529 | -0.757 | 0.160 | 4.886 | -0.058
M1 | 5 | 0.001 | medium | 0.1 | 2.979 | 3.778 | -0.645 | 0.497 | 0.998 | -0.007
S2 | 5 | 0.005 | small | 0.2 | 1.955 | 2.669 | -0.659 | 0.583 | 0.550 | -0.096
X1 | 5 | 0.001 | mixed | 0.2 | 0.446 | 6.042 | -0.257 | 0.648 | 0.497 | -0.030
S3 | 5 | 0.01 | small | 0.3 | 0.650 | 1.247 | -0.563 | 0.797 | 0.099 | -0.124
L1 | 5 | 0.001 | large | 0.6 | 0.094 | 0.687 | -0.445 | 0.954 | -0.046 | -0.090
M2 | 5 | 0.005 | medium | 0.6 | 0.078 | 0.674 | -0.448 | 0.946 | -0.056 | -0.107
X2 | 5 | 0.005 | mixed | 1.1 | 0.022 | 0.801 | -0.280 | 0.980 | -0.002 | -0.022
M3 | 5 | 0.01 | medium | 1.3 | -0.207 | 0.330 | -0.300 | 0.997 | -0.087 | -0.089
S4 | 5 | 0.05 | small | 1.7 | -0.240 | 0.198 | -0.261 | 1.000 | -0.101 | -0.101
X3 | 5 | 0.01 | mixed | 2.2 | -0.034 | 0.363 | -0.263 | 0.998 | -0.005 | -0.007
L2 | 5 | 0.005 | large | 3.2 | -0.221 | 0.091 | -0.167 | 1.000 | -0.093 | -0.093
S5 | 5 | 0.1 | small | 3.4 | -0.152 | 0.082 | -0.119 | 1.000 | -0.068 | -0.068
L3 | 5 | 0.01 | large | 6.4 | -0.134 | 0.014 | -0.100 | 1.000 | -0.089 | -0.089
M4 | 5 | 0.05 | medium | 6.4 | -0.117 | 0.012 | -0.090 | 0.999 | -0.082 | -0.082
X4 | 5 | 0.05 | mixed | 10.9 | -0.093 | 0.085 | -0.139 | 1.000 | -0.040 | -0.040
M5 | 5 | 0.1 | medium | 12.8 | -0.038 | -0.021 | -0.043 | 1.000 | -0.066 | -0.066
S6 | 5 | 0.4 | small | 13.7 | -0.014 | -0.020 | -0.028 | 1.000 | -0.044 | -0.044
S7 | 5 | 0.5 | small | 17.1 | -0.012 | -0.014 | -0.014 | 1.000 | -0.016 | -0.016
X5 | 5 | 0.1 | mixed | 21.9 | -0.111 | -0.007 | -0.124 | 1.000 | -0.088 | -0.088
L4 | 5 | 0.05 | large | 31.8 | -0.047 | -0.087 | -0.072 | 0.999 | -0.110 | -0.110
M6 | 5 | 0.4 | medium | 51.4 | -0.002 | -0.031 | -0.018 | 1.000 | -0.040 | -0.040
L5 | 5 | 0.1 | large | 63.7 | -0.013 | -0.081 | -0.049 | 1.000 | -0.092 | -0.092
M7 | 5 | 0.5 | medium | 64.2 | 0.001 | 0.000 | 0.001 | 1.000 | 0.001 | 0.001
X6 | 5 | 0.4 | mixed | 87.5 | -0.014 | -0.023 | -0.029 | 1.000 | -0.041 | -0.041
X7 | 5 | 0.5 | mixed | 109.4 | -0.009 | -0.007 | -0.010 | 0.999 | -0.012 | -0.011
L6 | 5 | 0.4 | large | 254.6 | 0.003 | -0.038 | -0.016 | 1.000 | -0.040 | -0.040
L7 | 5 | 0.5 | large | 318.3 | -0.005 | -0.007 | -0.006 | 1.000 | -0.008 | -0.008
S1 | 15 | 0.001 | small | <0.1 | 14.558 | 19.528 | -0.887 | 0.335 | -0.477 | -0.505
M1 | 15 | 0.001 | medium | 0.1 | 3.183 | 4.300 | -0.826 | 0.815 | -0.176 | -0.328
X1 | 15 | 0.001 | mixed | 0.1 | 0.940 | 6.034 | -0.661 | 0.864 | -0.094 | -0.217
S2 | 15 | 0.005 | small | 0.1 | 2.334 | 3.685 | -0.805 | 0.847 | -0.164 | -0.292
S3 | 15 | 0.01 | small | 0.3 | 0.841 | 1.761 | -0.695 | 0.977 | -0.168 | -0.187
M2 | 15 | 0.005 | medium | 0.6 | 0.096 | 0.815 | -0.559 | 1.000 | -0.140 | -0.140
L1 | 15 | 0.001 | large | 0.6 | 0.010 | 0.794 | -0.525 | 0.999 | -0.125 | -0.125
X2 | 15 | 0.005 | mixed | 0.7 | -0.084 | 0.971 | -0.465 | 1.000 | -0.108 | -0.108
M3 | 15 | 0.01 | medium | 1.1 | -0.259 | 0.431 | -0.389 | 1.000 | -0.113 | -0.113
X3 | 15 | 0.01 | mixed | 1.3 | -0.226 | 0.445 | -0.380 | 1.000 | -0.101 | -0.101
S4 | 15 | 0.05 | small | 1.4 | -0.304 | 0.340 | -0.350 | 1.000 | -0.122 | -0.122
S5 | 15 | 0.1 | small | 2.7 | -0.237 | 0.153 | -0.184 | 1.000 | -0.087 | -0.087
L2 | 15 | 0.005 | large | 3.1 | -0.274 | 0.155 | -0.191 | 0.999 | -0.097 | -0.097
M4 | 15 | 0.05 | medium | 5.7 | -0.168 | 0.032 | -0.118 | 1.000 | -0.102 | -0.102
L3 | 15 | 0.01 | large | 6.3 | -0.169 | 0.029 | -0.121 | 1.000 | -0.104 | -0.104
X4 | 15 | 0.05 | mixed | 6.7 | -0.157 | 0.068 | -0.150 | 1.000 | -0.084 | -0.084
S6 | 15 | 0.4 | small | 10.8 | -0.007 | -0.006 | -0.029 | 1.000 | -0.042 | -0.042
M5 | 15 | 0.1 | medium | 11.5 | -0.073 | -0.026 | -0.074 | 1.000 | -0.096 | -0.096
X5 | 15 | 0.1 | mixed | 13.4 | -0.107 | 0.002 | -0.098 | 1.000 | -0.090 | -0.090
S7 | 15 | 0.5 | small | 13.5 | 0.006 | 0.007 | 0.006 | 1.000 | 0.008 | 0.008
L4 | 15 | 0.05 | large | 31.4 | -0.038 | -0.074 | -0.063 | 1.000 | -0.105 | -0.105
M6 | 15 | 0.4 | medium | 45.9 | -0.009 | -0.044 | -0.030 | 1.000 | -0.057 | -0.057
X6 | 15 | 0.4 | mixed | 53.5 | -0.005 | -0.027 | -0.025 | 1.000 | -0.047 | -0.047
M7 | 15 | 0.5 | medium | 57.4 | -0.001 | -0.001 | -0.001 | 1.000 | -0.001 | -0.001
L5 | 15 | 0.1 | large | 62.8 | -0.014 | -0.085 | -0.053 | 1.000 | -0.101 | -0.101
X7 | 15 | 0.5 | mixed | 66.9 | 0.001 | 0.001 | 0.002 | 1.000 | 0.003 | 0.003
L6 | 15 | 0.4 | large | 251.4 | 0.003 | -0.043 | -0.018 | 1.000 | -0.046 | -0.046
L7 | 15 | 0.5 | large | 314.2 | -0.002 | -0.002 | -0.002 | 1.000 | -0.002 | -0.002
S1 | 30 | 0.001 | small | <0.1 | 14.019 | 19.604 | -0.937 | 0.546 | -0.677 | -0.823
M1 | 30 | 0.001 | medium | 0.1 | 3.359 | 4.686 | -0.849 | 0.956 | -0.346 | -0.375
X1 | 30 | 0.001 | mixed | 0.1 | 1.113 | 6.608 | -0.737 | 0.974 | -0.225 | -0.245
S2 | 30 | 0.005 | small | 0.1 | 2.248 | 3.744 | -0.819 | 0.978 | -0.311 | -0.326
S3 | 30 | 0.01 | small | 0.3 | 0.786 | 1.790 | -0.710 | 1.000 | -0.190 | -0.190
M2 | 30 | 0.005 | medium | 0.5 | 0.129 | 0.902 | -0.586 | 1.000 | -0.135 | -0.135
L1 | 30 | 0.001 | large | 0.5 | 0.081 | 0.922 | -0.576 | 1.000 | -0.126 | -0.126
X2 | 30 | 0.005 | mixed | 0.6 | -0.140 | 1.093 | -0.474 | 1.000 | -0.110 | -0.110
M3 | 30 | 0.01 | medium | 1.1 | -0.242 | 0.505 | -0.404 | 1.000 | -0.093 | -0.093
X3 | 30 | 0.01 | mixed | 1.3 | -0.287 | 0.539 | -0.358 | 1.000 | -0.096 | -0.096
S4 | 30 | 0.05 | small | 1.4 | -0.318 | 0.393 | -0.334 | 1.000 | -0.096 | -0.096
S5 | 30 | 0.1 | small | 2.7 | -0.243 | 0.167 | -0.194 | 0.999 | -0.096 | -0.095
L2 | 30 | 0.005 | large | 2.7 | -0.311 | 0.206 | -0.220 | 1.000 | -0.102 | -0.102
M4 | 30 | 0.05 | medium | 5.4 | -0.182 | 0.043 | -0.128 | 1.000 | -0.109 | -0.109
L3 | 30 | 0.01 | large | 5.5 | -0.190 | 0.056 | -0.131 | 1.000 | -0.103 | -0.103
X4 | 30 | 0.05 | mixed | 6.4 | -0.140 | 0.067 | -0.157 | 1.000 | -0.101 | -0.101
M5 | 30 | 0.1 | medium | 10.8 | -0.080 | -0.024 | -0.078 | 1.000 | -0.100 | -0.100
S6 | 30 | 0.4 | small | 10.9 | -0.005 | -0.005 | -0.029 | 1.000 | -0.043 | -0.043
X5 | 30 | 0.1 | mixed | 12.7 | -0.091 | -0.006 | -0.108 | 1.000 | -0.102 | -0.102
S7 | 30 | 0.5 | small | 13.6 | 0.002 | 0.002 | 0.003 | 1.000 | 0.003 | 0.003
L4 | 30 | 0.05 | large | 27.4 | -0.043 | -0.072 | -0.066 | 1.000 | -0.108 | -0.108
M6 | 30 | 0.4 | medium | 43.0 | -0.001 | -0.037 | -0.023 | 1.000 | -0.050 | -0.050
X6 | 30 | 0.4 | mixed | 50.8 | -0.002 | -0.026 | -0.024 | 1.000 | -0.045 | -0.045
M7 | 30 | 0.5 | medium | 53.8 | 0.003 | 0.004 | 0.004 | 1.000 | 0.005 | 0.005
L5 | 30 | 0.1 | large | 54.9 | -0.019 | -0.087 | -0.057 | 1.000 | -0.106 | -0.106
X7 | 30 | 0.5 | mixed | 63.5 | 0.002 | 0.001 | 0.001 | 1.000 | 0.001 | 0.001
L6 | 30 | 0.4 | large | 219.4 | -0.005 | -0.055 | -0.028 | 1.000 | -0.059 | -0.059
L7 | 30 | 0.5 | large | 274.3 | 0.005 | 0.006 | 0.005 | 1.000 | 0.006 | 0.006

“Discrete” stands for discrete likelihood methods. Scenarios are ordered by number of studies (K), and then by expected count. Bold horizontal lines separate scenarios by number of studies. White and grey shading separates scenarios with expected counts ≤1, between 1 and 5, and ≥5. We code scenarios using two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1, 6=0.4, 7=0.5).

The column “Discrete (fraction converged)” shows the proportion of simulations for which random effects methods converged successfully. Values of 1.000 mean that random effects methods converged successfully in all 1000 simulations in a scenario, and a value of e.g., 0.335 means that they converged in 335 out of 1000 simulations in a scenario. The columns “Discrete (random)” and “Discrete (hybrid)” are identical when the fraction converged is 1.000, because the random effects method was used in all simulations.

Table 7 Comparison of proportion RMSE across random effects methods (selected scenarios with high heterogeneity)

Scenario | K | Proportion | Sample size | Exp count | Approximate untransformed | Approximate logit | Approximate arcsine | Discrete (fraction converged) | Discrete (random) | Discrete (hybrid)
S1 | 5 | 0.001 | small | <0.1 | 12.407 | 14.631 | 1.025 | 0.160 | 5.211 | 2.277
M1 | 5 | 0.001 | medium | 0.1 | 3.018 | 3.924 | 0.905 | 0.497 | 1.483 | 1.263
S2 | 5 | 0.005 | small | 0.2 | 2.002 | 2.804 | 0.838 | 0.583 | 1.004 | 1.002
X1 | 5 | 0.001 | mixed | 0.2 | 1.095 | 6.098 | 0.838 | 0.648 | 1.022 | 1.014
S3 | 5 | 0.01 | small | 0.3 | 0.733 | 1.442 | 0.760 | 0.797 | 0.685 | 0.759
L1 | 5 | 0.001 | large | 0.6 | 0.317 | 0.919 | 0.658 | 0.954 | 0.576 | 0.602
M2 | 5 | 0.005 | medium | 0.6 | 0.289 | 0.912 | 0.660 | 0.946 | 0.567 | 0.598
X2 | 5 | 0.005 | mixed | 1.1 | 0.595 | 0.965 | 0.545 | 0.980 | 0.576 | 0.587
M3 | 5 | 0.01 | medium | 1.3 | 0.366 | 0.569 | 0.528 | 0.997 | 0.458 | 0.461
S4 | 5 | 0.05 | small | 1.7 | 0.391 | 0.437 | 0.473 | 1.000 | 0.404 | 0.404
X3 | 5 | 0.01 | mixed | 2.2 | 0.466 | 0.609 | 0.513 | 0.998 | 0.491 | 0.493
L2 | 5 | 0.005 | large | 3.2 | 0.391 | 0.352 | 0.391 | 1.000 | 0.357 | 0.357
S5 | 5 | 0.1 | small | 3.4 | 0.354 | 0.316 | 0.352 | 1.000 | 0.323 | 0.323
L3 | 5 | 0.01 | large | 6.4 | 0.320 | 0.285 | 0.308 | 1.000 | 0.299 | 0.299
M4 | 5 | 0.05 | medium | 6.4 | 0.312 | 0.277 | 0.304 | 0.999 | 0.296 | 0.296
X4 | 5 | 0.05 | mixed | 10.9 | 0.340 | 0.366 | 0.373 | 1.000 | 0.364 | 0.364
M5 | 5 | 0.1 | medium | 12.8 | 0.266 | 0.252 | 0.260 | 1.000 | 0.264 | 0.264
S6 | 5 | 0.4 | small | 13.7 | 0.255 | 0.259 | 0.267 | 1.000 | 0.283 | 0.283
S7 | 5 | 0.5 | small | 17.1 | 0.247 | 0.262 | 0.268 | 1.000 | 0.295 | 0.295
X5 | 5 | 0.1 | mixed | 21.9 | 0.296 | 0.283 | 0.307 | 1.000 | 0.304 | 0.304
L4 | 5 | 0.05 | large | 31.8 | 0.240 | 0.241 | 0.239 | 0.999 | 0.253 | 0.253
M6 | 5 | 0.4 | medium | 51.4 | 0.242 | 0.266 | 0.254 | 1.000 | 0.275 | 0.275
L5 | 5 | 0.1 | large | 63.7 | 0.243 | 0.242 | 0.239 | 1.000 | 0.248 | 0.248
M7 | 5 | 0.5 | medium | 64.2 | 0.221 | 0.264 | 0.243 | 1.000 | 0.278 | 0.278
X6 | 5 | 0.4 | mixed | 87.5 | 0.257 | 0.267 | 0.270 | 1.000 | 0.284 | 0.284
X7 | 5 | 0.5 | mixed | 109.4 | 0.246 | 0.272 | 0.267 | 0.999 | 0.294 | 0.295
L6 | 5 | 0.4 | large | 254.6 | 0.222 | 0.253 | 0.235 | 1.000 | 0.256 | 0.256
L7 | 5 | 0.5 | large | 318.3 | 0.226 | 0.281 | 0.250 | 1.000 | 0.287 | 0.287
S1 | 15 | 0.001 | small | <0.1 | 14.568 | 19.564 | 0.926 | 0.335 | 1.882 | 1.361
M1 | 15 | 0.001 | medium | 0.1 | 3.193 | 4.348 | 0.854 | 0.815 | 0.812 | 0.850
X1 | 15 | 0.001 | mixed | 0.1 | 1.233 | 6.072 | 0.759 | 0.864 | 0.721 | 0.765
S2 | 15 | 0.005 | small | 0.1 | 2.347 | 3.738 | 0.838 | 0.847 | 0.733 | 0.780
S3 | 15 | 0.01 | small | 0.3 | 0.866 | 1.834 | 0.744 | 0.977 | 0.564 | 0.578
M2 | 15 | 0.005 | medium | 0.6 | 0.179 | 0.910 | 0.617 | 1.000 | 0.405 | 0.405
L1 | 15 | 0.001 | large | 0.6 | 0.161 | 0.892 | 0.592 | 0.999 | 0.397 | 0.398
X2 | 15 | 0.005 | mixed | 0.7 | 0.362 | 1.042 | 0.543 | 1.000 | 0.410 | 0.410
M3 | 15 | 0.01 | medium | 1.1 | 0.294 | 0.532 | 0.463 | 1.000 | 0.299 | 0.299
X3 | 15 | 0.01 | mixed | 1.3 | 0.354 | 0.542 | 0.456 | 1.000 | 0.313 | 0.313
S4 | 15 | 0.05 | small | 1.4 | 0.347 | 0.434 | 0.430 | 1.000 | 0.291 | 0.291
S5 | 15 | 0.1 | small | 2.7 | 0.310 | 0.247 | 0.283 | 1.000 | 0.226 | 0.226
L2 | 15 | 0.005 | large | 3.1 | 0.331 | 0.250 | 0.279 | 0.999 | 0.222 | 0.222
M4 | 15 | 0.05 | medium | 5.7 | 0.240 | 0.167 | 0.207 | 1.000 | 0.195 | 0.195
L3 | 15 | 0.01 | large | 6.3 | 0.238 | 0.166 | 0.208 | 1.000 | 0.193 | 0.193
X4 | 15 | 0.05 | mixed | 6.7 | 0.239 | 0.203 | 0.243 | 1.000 | 0.209 | 0.209
S6 | 15 | 0.4 | small | 10.8 | 0.148 | 0.147 | 0.160 | 1.000 | 0.169 | 0.169
M5 | 15 | 0.1 | medium | 11.5 | 0.164 | 0.140 | 0.160 | 1.000 | 0.170 | 0.170
X5 | 15 | 0.1 | mixed | 13.4 | 0.196 | 0.164 | 0.192 | 1.000 | 0.186 | 0.186
S7 | 15 | 0.5 | small | 13.5 | 0.135 | 0.147 | 0.156 | 1.000 | 0.173 | 0.173
L4 | 15 | 0.05 | large | 31.4 | 0.149 | 0.154 | 0.153 | 1.000 | 0.173 | 0.173
M6 | 15 | 0.4 | medium | 45.9 | 0.135 | 0.157 | 0.148 | 1.000 | 0.167 | 0.167
X6 | 15 | 0.4 | mixed | 53.5 | 0.142 | 0.156 | 0.153 | 1.000 | 0.168 | 0.168
M7 | 15 | 0.5 | medium | 57.4 | 0.132 | 0.161 | 0.148 | 1.000 | 0.172 | 0.172
L5 | 15 | 0.1 | large | 62.8 | 0.136 | 0.156 | 0.142 | 1.000 | 0.166 | 0.166
X7 | 15 | 0.5 | mixed | 66.9 | 0.136 | 0.161 | 0.153 | 1.000 | 0.176 | 0.176
L6 | 15 | 0.4 | large | 251.4 | 0.128 | 0.154 | 0.138 | 1.000 | 0.156 | 0.156
L7 | 15 | 0.5 | large | 314.2 | 0.129 | 0.165 | 0.145 | 1.000 | 0.170 | 0.170
S1 | 30 | 0.001 | small | <0.1 | 14.024 | 19.618 | 0.944 | 0.546 | 1.072 | 1.040
M1 | 30 | 0.001 | medium | 0.1 | 3.365 | 4.713 | 0.862 | 0.956 | 0.732 | 0.746
X1 | 30 | 0.001 | mixed | 0.1 | 1.225 | 6.628 | 0.775 | 0.974 | 0.623 | 0.635
S2 | 30 | 0.005 | small | 0.1 | 2.255 | 3.771 | 0.835 | 0.978 | 0.661 | 0.670
S3 | 30 | 0.01 | small | 0.3 | 0.798 | 1.825 | 0.734 | 1.000 | 0.459 | 0.459
M2 | 30 | 0.005 | medium | 0.5 | 0.173 | 0.957 | 0.615 | 1.000 | 0.325 | 0.325
L1 | 30 | 0.001 | large | 0.5 | 0.144 | 0.973 | 0.605 | 1.000 | 0.317 | 0.317
X2 | 30 | 0.005 | mixed | 0.6 | 0.271 | 1.126 | 0.513 | 1.000 | 0.295 | 0.295
M3 | 30 | 0.01 | medium | 1.1 | 0.261 | 0.561 | 0.440 | 1.000 | 0.223 | 0.223
X3 | 30 | 0.01 | mixed | 1.3 | 0.337 | 0.584 | 0.406 | 1.000 | 0.234 | 0.234
S4 | 30 | 0.05 | small | 1.4 | 0.340 | 0.441 | 0.379 | 1.000 | 0.214 | 0.214
S5 | 30 | 0.1 | small | 2.7 | 0.281 | 0.214 | 0.243 | 0.999 | 0.170 | 0.170
L2 | 30 | 0.005 | large | 2.7 | 0.339 | 0.254 | 0.266 | 1.000 | 0.179 | 0.179
M4 | 30 | 0.05 | medium | 5.4 | 0.217 | 0.120 | 0.174 | 1.000 | 0.157 | 0.157
L3 | 30 | 0.01 | large | 5.5 | 0.223 | 0.129 | 0.179 | 1.000 | 0.157 | 0.157
X4 | 30 | 0.05 | mixed | 6.4 | 0.192 | 0.149 | 0.205 | 1.000 | 0.166 | 0.166
M5 | 30 | 0.1 | medium | 10.8 | 0.136 | 0.107 | 0.133 | 1.000 | 0.147 | 0.147
S6 | 30 | 0.4 | small | 10.9 | 0.109 | 0.110 | 0.121 | 1.000 | 0.129 | 0.129
X5 | 30 | 0.1 | mixed | 12.7 | 0.144 | 0.111 | 0.156 | 1.000 | 0.151 | 0.151
S7 | 30 | 0.5 | small | 13.6 | 0.105 | 0.114 | 0.123 | 1.000 | 0.135 | 0.135
L4 | 30 | 0.05 | large | 27.4 | 0.107 | 0.117 | 0.114 | 1.000 | 0.142 | 0.142
M6 | 30 | 0.4 | medium | 43.0 | 0.092 | 0.109 | 0.101 | 1.000 | 0.118 | 0.118
X6 | 30 | 0.4 | mixed | 50.8 | 0.099 | 0.110 | 0.110 | 1.000 | 0.123 | 0.123
M7 | 30 | 0.5 | medium | 53.8 | 0.091 | 0.113 | 0.104 | 1.000 | 0.123 | 0.123
L5 | 30 | 0.1 | large | 54.9 | 0.095 | 0.125 | 0.107 | 1.000 | 0.140 | 0.140
X7 | 30 | 0.5 | mixed | 63.5 | 0.099 | 0.118 | 0.113 | 1.000 | 0.129 | 0.129
L6 | 30 | 0.4 | large | 219.4 | 0.092 | 0.121 | 0.103 | 1.000 | 0.124 | 0.124
L7 | 30 | 0.5 | large | 274.3 | 0.096 | 0.124 | 0.108 | 1.000 | 0.127 | 0.127

“Discrete” stands for discrete likelihood methods. Scenarios are ordered by number of studies (K), and then by expected count. Bold horizontal lines separate scenarios by number of studies. White and grey shading separates scenarios with expected counts ≤1, between 1 and 5, and ≥5. We code scenarios using two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1, 6=0.4, 7=0.5).

The column “Discrete (fraction converged)” shows the proportion of simulations for which random effects methods converged successfully. Values of 1.000 mean that random effects methods converged successfully in all 1000 simulations in a scenario, and a value of e.g., 0.335 means that they converged in 335 out of 1000 simulations in a scenario. The columns “Discrete (random)” and “Discrete (hybrid)” are identical when the fraction converged is 1.000, because the random effects method was used in all simulations.

Table 8 Comparison of coverage across random effects methods (selected scenarios with high heterogeneity)

Scenario | K | Proportion | Sample size | Exp count | Approximate untransformed | Approximate logit | Approximate arcsine | Discrete (fraction converged) | Discrete (random) | Discrete (hybrid)
S1 | 5 | 0.001 | small | <0.1 | 1.000 | 0.000 | 1.000 | 0.160 | 0.931 | 0.989
M1 | 5 | 0.001 | medium | 0.1 | 1.000 | 0.000 | 0.997 | 0.497 | 0.938 | 0.969
S2 | 5 | 0.005 | small | 0.2 | 1.000 | 0.417 | 1.000 | 0.583 | 0.938 | 0.964
X1 | 5 | 0.001 | mixed | 0.2 | 0.992 | 0.000 | 0.645 | 0.648 | 0.966 | 0.978
S3 | 5 | 0.01 | small | 0.3 | 0.999 | 0.766 | 0.796 | 0.797 | 0.976 | 0.981
L1 | 5 | 0.001 | large | 0.6 | 1.000 | 0.833 | 0.815 | 0.954 | 0.960 | 0.962
M2 | 5 | 0.005 | medium | 0.6 | 1.000 | 0.844 | 0.806 | 0.946 | 0.963 | 0.965
X2 | 5 | 0.005 | mixed | 1.1 | 0.814 | 0.798 | 0.826 | 0.980 | 0.941 | 0.922
M3 | 5 | 0.01 | medium | 1.3 | 0.926 | 0.896 | 0.842 | 0.997 | 0.972 | 0.969
S4 | 5 | 0.05 | small | 1.7 | 0.755 | 0.923 | 0.879 | 1.000 | 0.958 | 0.958
X3 | 5 | 0.01 | mixed | 2.2 | 0.763 | 0.824 | 0.797 | 0.998 | 0.841 | 0.839
L2 | 5 | 0.005 | large | 3.2 | 0.701 | 0.923 | 0.891 | 1.000 | 0.928 | 0.928
S5 | 5 | 0.1 | small | 3.4 | 0.769 | 0.938 | 0.906 | 1.000 | 0.918 | 0.918
L3 | 5 | 0.01 | large | 6.4 | 0.776 | 0.911 | 0.880 | 1.000 | 0.889 | 0.889
M4 | 5 | 0.05 | medium | 6.4 | 0.768 | 0.908 | 0.870 | 0.999 | 0.882 | 0.881
X4 | 5 | 0.05 | mixed | 10.9 | 0.717 | 0.740 | 0.828 | 1.000 | 0.702 | 0.702
M5 | 5 | 0.1 | medium | 12.8 | 0.830 | 0.878 | 0.866 | 1.000 | 0.849 | 0.849
S6 | 5 | 0.4 | small | 13.7 | 0.861 | 0.880 | 0.875 | 1.000 | 0.859 | 0.859
S7 | 5 | 0.5 | small | 17.1 | 0.853 | 0.860 | 0.864 | 1.000 | 0.850 | 0.850
X5 | 5 | 0.1 | mixed | 21.9 | 0.723 | 0.819 | 0.815 | 1.000 | 0.750 | 0.750
L4 | 5 | 0.05 | large | 31.8 | 0.825 | 0.866 | 0.861 | 0.999 | 0.842 | 0.842
M6 | 5 | 0.4 | medium | 51.4 | 0.835 | 0.832 | 0.841 | 1.000 | 0.815 | 0.815
L5 | 5 | 0.1 | large | 63.7 | 0.840 | 0.847 | 0.861 | 1.000 | 0.829 | 0.829
M7 | 5 | 0.5 | medium | 64.2 | 0.887 | 0.864 | 0.891 | 1.000 | 0.867 | 0.867
X6 | 5 | 0.4 | mixed | 87.5 | 0.827 | 0.854 | 0.835 | 1.000 | 0.828 | 0.828
X7 | 5 | 0.5 | mixed | 109.4 | 0.826 | 0.837 | 0.838 | 0.999 | 0.836 | 0.835
L6 | 5 | 0.4 | large | 254.6 | 0.877 | 0.852 | 0.872 | 1.000 | 0.853 | 0.853
L7 | 5 | 0.5 | large | 318.3 | 0.865 | 0.829 | 0.871 | 1.000 | 0.845 | 0.845
S1 | 15 | 0.001 | small | <0.1 | 0.000 | 0.000 | 1.000 | 0.335 | 0.872 | 0.957
M1 | 15 | 0.001 | medium | 0.1 | 0.215 | 0.000 | 0.500 | 0.815 | 0.979 | 0.983
X1 | 15 | 0.001 | mixed | 0.1 | 0.964 | 0.000 | 0.653 | 0.864 | 0.956 | 0.962
S2 | 15 | 0.005 | small | 0.1 | 0.806 | 0.000 | 0.570 | 0.847 | 0.967 | 0.972
S3 | 15 | 0.01 | small | 0.3 | 0.996 | 0.023 | 0.479 | 0.977 | 0.988 | 0.965
M2 | 15 | 0.005 | medium | 0.6 | 0.999 | 0.463 | 0.551 | 1.000 | 0.975 | 0.975
L1 | 15 | 0.001 | large | 0.6 | 1.000 | 0.468 | 0.572 | 0.999 | 0.957 | 0.956
X2 | 15 | 0.005 | mixed | 0.7 | 0.788 | 0.295 | 0.636 | 1.000 | 0.953 | 0.953
M3 | 15 | 0.01 | medium | 1.1 | 0.781 | 0.653 | 0.690 | 1.000 | 0.974 | 0.974
X3 | 15 | 0.01 | mixed | 1.3 | 0.668 | 0.623 | 0.703 | 1.000 | 0.919 | 0.919
S4 | 15 | 0.05 | small | 1.4 | 0.527 | 0.711 | 0.739 | 1.000 | 0.946 | 0.946
S5 | 15 | 0.1 | small | 2.7 | 0.571 | 0.847 | 0.841 | 1.000 | 0.921 | 0.921
L2 | 15 | 0.005 | large | 3.1 | 0.506 | 0.839 | 0.828 | 0.999 | 0.928 | 0.928
M4 | 15 | 0.05 | medium | 5.7 | 0.684 | 0.925 | 0.878 | 1.000 | 0.885 | 0.885
L3 | 15 | 0.01 | large | 6.3 | 0.671 | 0.914 | 0.863 | 1.000 | 0.889 | 0.889
X4 | 15 | 0.05 | mixed | 6.7 | 0.695 | 0.862 | 0.841 | 1.000 | 0.900 | 0.900
S6 | 15 | 0.4 | small | 10.8 | 0.932 | 0.922 | 0.923 | 1.000 | 0.918 | 0.918
M5 | 15 | 0.1 | medium | 11.5 | 0.846 | 0.928 | 0.898 | 1.000 | 0.883 | 0.883
X5 | 15 | 0.1 | mixed | 13.4 | 0.774 | 0.909 | 0.860 | 1.000 | 0.873 | 0.873
S7 | 15 | 0.5 | small | 13.5 | 0.953 | 0.923 | 0.939 | 1.000 | 0.933 | 0.933
L4 | 15 | 0.05 | large | 31.4 | 0.860 | 0.868 | 0.874 | 1.000 | 0.844 | 0.844
M6 | 15 | 0.4 | medium | 45.9 | 0.934 | 0.885 | 0.912 | 1.000 | 0.904 | 0.904
X6 | 15 | 0.4 | mixed | 53.5 | 0.920 | 0.896 | 0.909 | 1.000 | 0.905 | 0.905
M7 | 15 | 0.5 | medium | 57.4 | 0.959 | 0.877 | 0.940 | 1.000 | 0.935 | 0.935
L5 | 15 | 0.1 | large | 62.8 | 0.890 | 0.857 | 0.897 | 1.000 | 0.860 | 0.860
X7 | 15 | 0.5 | mixed | 66.9 | 0.939 | 0.892 | 0.917 | 1.000 | 0.931 | 0.931
L6 | 15 | 0.4 | large | 251.4 | 0.939 | 0.880 | 0.931 | 1.000 | 0.920 | 0.920
L7 | 15 | 0.5 | large | 314.2 | 0.948 | 0.857 | 0.920 | 1.000 | 0.919 | 0.919
S1 | 30 | 0.001 | small | <0.1 | 0.000 | 0.000 | 1.000 | 0.546 | 0.963 | 0.980
M1 | 30 | 0.001 | medium | 0.1 | 0.000 | 0.000 | 0.274 | 0.956 | 0.976 | 0.977
X1 | 30 | 0.001 | mixed | 0.1 | 0.826 | 0.000 | 0.405 | 0.974 | 0.972 | 0.947
S2 | 30 | 0.005 | small | 0.1 | 0.000 | 0.000 | 0.224 | 0.978 | 0.983 | 0.961
S3 | 30 | 0.01 | small | 0.3 | 0.857 | 0.000 | 0.197 | 1.000 | 0.977 | 0.977
M2 | 30 | 0.005 | medium | 0.5 | 1.000 | 0.112 | 0.284 | 1.000 | 0.974 | 0.974
L1 | 30 | 0.001 | large | 0.5 | 0.999 | 0.074 | 0.295 | 1.000 | 0.978 | 0.978
X2 | 30 | 0.005 | mixed | 0.6 | 0.814 | 0.009 | 0.420 | 1.000 | 0.963 | 0.963
M3 | 30 | 0.01 | medium | 1.1 | 0.666 | 0.326 | 0.501 | 1.000 | 0.965 | 0.965
X3 | 30 | 0.01 | mixed | 1.3 | 0.447 | 0.244 | 0.545 | 1.000 | 0.939 | 0.939
S4 | 30 | 0.05 | small | 1.4 | 0.266 | 0.412 | 0.580 | 1.000 | 0.936 | 0.936
S5 | 30 | 0.1 | small | 2.7 | 0.425 | 0.755 | 0.765 | 0.999 | 0.919 | 0.919
L2 | 30 | 0.005 | large | 2.7 | 0.245 | 0.667 | 0.707 | 1.000 | 0.916 | 0.916
M4 | 30 | 0.05 | medium | 5.4 | 0.553 | 0.925 | 0.831 | 1.000 | 0.862 | 0.862
L3 | 30 | 0.01 | large | 5.5 | 0.505 | 0.920 | 0.810 | 1.000 | 0.879 | 0.879
X4 | 30 | 0.05 | mixed | 6.4 | 0.666 | 0.871 | 0.752 | 1.000 | 0.861 | 0.861
M5 | 30 | 0.1 | medium | 10.8 | 0.800 | 0.930 | 0.852 | 1.000 | 0.823 | 0.823
S6 | 30 | 0.4 | small | 10.9 | 0.934 | 0.920 | 0.921 | 1.000 | 0.914 | 0.914
X5 | 30 | 0.1 | mixed | 12.7 | 0.789 | 0.936 | 0.847 | 1.000 | 0.869 | 0.869
S7 | 30 | 0.5 | small | 13.6 | 0.953 | 0.909 | 0.922 | 1.000 | 0.925 | 0.925
L4 | 30 | 0.05 | large | 27.4 | 0.877 | 0.876 | 0.892 | 1.000 | 0.800 | 0.800
M6 | 30 | 0.4 | medium | 43.0 | 0.960 | 0.902 | 0.930 | 1.000 | 0.916 | 0.916
X6 | 30 | 0.4 | mixed | 50.8 | 0.956 | 0.912 | 0.930 | 1.000 | 0.930 | 0.930
M7 | 30 | 0.5 | medium | 53.8 | 0.976 | 0.884 | 0.941 | 1.000 | 0.941 | 0.941
L5 | 30 | 0.1 | large | 54.9 | 0.911 | 0.825 | 0.901 | 1.000 | 0.813 | 0.813
X7 | 30 | 0.5 | mixed | 63.5 | 0.952 | 0.880 | 0.921 | 1.000 | 0.930 | 0.930
L6 | 30 | 0.4 | large | 219.4 | 0.953 | 0.850 | 0.927 | 1.000 | 0.906 | 0.906
L7 | 30 | 0.5 | large | 274.3 | 0.961 | 0.847 | 0.935 | 1.000 | 0.931 | 0.931

“Discrete” stands for discrete likelihood methods. Scenarios are ordered by number of studies (K), and then by expected count. Bold horizontal lines separate scenarios by number of studies. White and grey shading separates scenarios with expected counts ≤1, between 1 and 5, and ≥5. We code scenarios using two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1, 6=0.4, 7=0.5). The column “Discrete (fraction converged)” shows the proportion of simulations for which random effects methods converged successfully. Values of 1.000 mean that random effects methods converged successfully in all 1000 simulations in a scenario, and a value of e.g., 0.335 means that they converged in 335 out of 1000 simulations in a scenario. The columns “Discrete (random)” and “Discrete (hybrid)” are identical when the fraction converged is 1.000, because the random effects method was used in all simulations.

In each table, scenarios are ordered by number of studies (K), and then by expected count. Bold horizontal lines separate scenarios by number of studies. White and grey shading separates scenarios with expected counts ≤1, between 1 and 5, and ≥5. We code scenarios using two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1, 6=0.4).

Results from the five different models are displayed in the last six columns along with the column labeled “Discrete (fraction converged)” which shows the proportion of simulations for which random effects methods converged successfully. Values of 1.000 mean that random effects methods converged successfully in all 1000 simulations in a scenario, and a value of e.g., 0.335 means that they converged in 335 out of 1000 simulations in a scenario. The columns “Discrete (random)” and “Discrete (hybrid)” are identical when the fraction converged is 1.000, because the random effects method was used in all simulations.

As an example, the first row of Table 6 describes the proportion bias for a simulation of five studies using a true proportion of 0.001 with small sample sizes (5-50 per study) in which the expected number of events (counts) is less than 0.1. This scenario is labeled S1. Results show that the inverse variance weight method using the proportion or the logit proportion estimates proportions that are between 12 and 15 times the size of the true proportion (i.e., estimated as 0.012 to 0.015, whereas the arcsine method estimates a mean that is 75 percent below the true proportion (i.e., is 0.00025). The discrete likelihood method converges only 16 percent of the time and when it does produces estimates that are nearly 5 times greater than 0.001 on average. Combining this with a fixed effect estimate when the method does not converge reduces this bias to only 5.8 percent.

We make the following general observations for scenarios with expected counts 1 or less, between 1 and 5, and 5 or more:

- For expected counts ≤1, the hybrid method has proportion bias and RMSE that are closer to zero and coverage probability closer to 95 percent compared to other methods.
- For expected counts between 1 and 5 the random effects discrete likelihood method and the approximate method with the variance stabilizing transformation have comparable performance, and perform better than other methods.

[For detailed descriptions and explanations, refer to these two sections: Pairwise Comparisons Among Approximate Methods—Random Effects Meta-Analysis, and Pairwise Comparisons Between Approximate and Discrete Likelihood Methods for Random Effects Meta-Analysis]

- For expected counts of 5 or more, the differences between methods become less evident.

For numerical reasons, the random effects discrete likelihood method does not always converge. The following general comments can be made:

- For very small expected counts (<0.5) and K≤15 the random effects discrete likelihood method reached convergence for fewer than 90 percent of the simulations (see column “Discrete (fraction converged)”). For expected counts above 1 and K=30, the method converges practically for all simulations (when the fraction converged equals 1.0, random effects methods converged in all simulations).
- For expected counts above 1 the random effect discrete likelihood method converged (almost) always, and thus the performance of the hybrid strategy is identical to that with random effects (discrete likelihood).

The random effects discrete likelihood method will not converge when all (or almost all) studies in a meta-analysis have 0 events. This is more common in simulation scenarios with very low expected counts, and when the number of studies is small.

We can make the following general comments on the preferred methods (hybrid strategy-discrete likelihood and variance-stabilizing transformation-approximate likelihood):

- For expected counts above 30, the approximate method using the variance stabilizing transformation has smaller absolute proportion bias and proportion RMSE than the discrete likelihood methods. For smaller counts, the methods using the discrete likelihood have smaller absolute proportion bias and proportion RMSE than the approximate method using the variance stabilizing transformation.

[For detailed descriptions and explanations, refer to Pairwise Comparisons Between Approximate and Discrete Likelihood Methods for Random Effects Meta-Analysis]

- For very large expected counts (for example when the true proportion is 0.4) all compared methods converge in proportion bias and proportion RMSE.

This is congruent with what we expect theoretically: the normal approximation to the binomial improves with increasing expected counts.

The hybrid strategy using the discrete likelihood has better coverage probabilities than the other methods for the widest range of scenarios.

### Pairwise Comparisons Among Approximate Methods—Random Effects Meta-Analysis

For random effects meta-analysis, results based on the variance stabilizing (arcsine) transformation have proportion bias and proportion RMSE closer to zero, and coverage probabilities closer to 95 percent, compared to those based on the canonical (logit) transformation or on untransformed data across a wide range of scenarios, as explained below.

Therefore, if one has to use approximate methods for random effects meta-analysis of proportions, we would recommend the variance stabilizing transformation.

#### No Transformation Versus Canonical Transformation (Logit Transformation)

Figure 2 compares the proportion bias for random effects meta-analysis on untransformed versus logit-transformed data. Its 9 panels are arranged in 3 columns, according to whether the mean expected number of events in the simulated studies is ≤1, between 1 and 5, or ≥ 5; and 3 rows, corresponding to the number of studies, K, in the simulated meta-analysis (5, 15, or 30). In Figure 2, points represent simulation scenarios, and are coded with a letter-number pair, based on sample size and true proportion. Each letter-number pair appears exactly once in each row of plots, as mapped in Table 9.

Figure 2 Comparison of proportion bias between approximate methods: no transformation versus canonical transformation (logit)

Rows correspond to number of studies. Columns correspond to ranges of expected count. Points on the dashed line have equal proportion bias for both methods. Points indicate simulation scenarios, and are coded with two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1). Black color indicates scenarios with small heterogeneity, and red scenarios with large heterogeneity. Only a representative subset of scenarios is plotted. The solid black reference lines indicate 0 bias. Note the change in scale across columns.

The diagram shows 9 scatter plots of scaled bias in a 3-by-3 array. Each scatter plot shows the scaled bias for logit-transformed data on the x-axis versus the scaled bias for untransformed data on the y-axis, for a number of points corresponding to different true proportions (.001, .005, .01, .05, .1) and sample-size scenarios (small, medium, large, and mixed). The rows of the array, from top to bottom, correspond to 5, 15, and 30 studies, respectively. The columns of the array, from left to right, correspond to the following ranges of expected counts: less than 1, between 1 and 5, and greater than 5.

Table 9 Mapping of simulation scenarios in the figures of the results section

Studies (K) | Expected count ≤ 1 | 1 < Expected count < 5 | Expected count ≥ 5
5 | S1, S2, S3, M1, M2, L1, X1 | S4, S5, M3, L2, [underlined: X2], X3 | M4, M5, L3, L4, L5, X4, X5
15 | S1, S2, S3, M1, M2, L1, X1, [underlined: X2] | S4, S5, M3, L2, X3 | M4, M5, L3, L4, L5, X4, X5
30 | S1, S2, S3, M1, M2, L1, X1, [underlined: X2] | S4, S5, M3, L2, X3 | M4, M5, L3, L4, L5, X4, X5

Simulation scenarios are coded with two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1). With a single exception, the various simulation scenarios map to the same range of expected count across all three choices of K (i.e., they map to the same row). The single exception pertains to X2 (i.e., scenarios with mixed sample sizes, and a true proportion equal to 0.002; underlined). For K=5, the expected count for X2 is 1.09; and for K=15 and K=30 the expected count is 0.67 and 0.64, respectively. This chance variation occurs because the sample sizes were chosen randomly for each K, and consequently the expected counts for all scenarios are different for 5 studies than for 15 or 30 studies. It so happens that for X2, this variation results in “changing columns.”

Figure 3 has a similar layout and, denotes the proportion RMSE, which behaves approximately the same as the absolute value of proportion bias (see Methods). Based on the two figures, we make the following observations:

Within each column of Figure 2, the location of the graphed points (simulation scenarios) is quite similar, especially considering that the exact sample sizes (and thus the expected counts) differ across values of K (see Categorizing Simulation Scenarios by Expected Counts per Study). The same observation applies to Figure 3 as well. For both methods, the proportion bias and the proportion RMSE do not change materially with the number of studies, K.

The influence of the number of studies on proportion bias (and the proportion RMSE) is small.

- For both methods, the proportion RMSE is generally highest for scenarios with expected counts <1, and tends to be smaller for higher expected counts. The absolute value of proportion bias follows a similar pattern.

The normal approximations to the binomial are better as the expected count increases, and this translates to better values for proportion bias and proportion RMSE. Further, continuity corrections are more likely to be necessary when the expected count is less than 1; as discussed in the 5^th^ bullet, continuity corrections introduce an upward bias for both methods.

- For expected counts less than 1, proportion bias and proportion RMSE are not very different between scenarios with smaller and larger heterogeneity: the red and black colored points are very near each other in Figure 2 and Figure 3. All other things being equal, proportion RMSE differs between smaller and larger heterogeneity scenarios when the expected counts are larger than 1 (Figure 4; and similarly for the absolute value of proportion bias—not shown).

For small expected counts, the estimate of between study heterogeneity is very often 0 or close to 0, and this attenuates any differences between scenarios with smaller and larger simulated heterogeneity.

- When the expected count is less than 5, differences in proportion bias (and proportion RMSE) between small and large heterogeneity scenarios are most pronounced for the logit transformation: Within each plot, the difference between red and black colored labels is larger along the horizontal axis compared to the vertical.

A likely explanation pertains to the “floor effect” of the untransformed data; small proportions are bounded by 0. In contrast, the logit transformation “expands” small proportion values to occupy the whole negative real axis, effectively removing the “floor effect”. This allows the summary estimate to be more influenced by studies with smaller proportion values, which are more likely to be drawn in simulations with large heterogeneity.

- Analytically, we expect the proportion bias of the summary estimate to be negative for untransformed data, and positive for logit-transformed data. The use of continuity corrections (cc) adds an additional bias component. This additional bias component can be positive, zero, or negative, for (cc)/(n_j , k_) > π_j_ , (cc)/(n_j , k_) = π_j_ , or (cc)/(n_j , k_) < π_j_ , respectively.

Proportion bias (for both transformed and untransformed data) can be positive, zero, or negative, depending on the relative magnitude of the two bias components, i.e., the bias component related to the mathematical transformation and that related to the correction factors. As heterogeneity increases, it is more difficult to make qualitative predictions for the proportion bias.

- For both methods, coverage is better when the expected count is at least 5 (Figure 5), compared to ≤ 1 or between 1 and 5.

The normal distribution approximates the binomial better as expected counts increase above 5.

- For expected counts ≥5, coverage is better for the canonical (logit) transformation compared to the untransformed data.
- For expected counts ≤1, the coverage is very often 100 percent for the untransformed data or 0 percent for the logit transformation.

For expected counts ≤ 1, continuity corrections are often needed for both approximate methods. For untransformed data, the combination of a positive bias (associated with the use of the continuity corrections) and the fact that the lower confidence interval can reach all the way to 0 (“floor effect”) may explain the 100 percent coverage.

- Coverage appears to become worse with increasing K. This is more evident for expected counts between 1 and 5.

We see no obvious explanation for this pattern.

Figure 3 Comparison of proportion RMSE between approximate methods: no transformation versus canonical transformation (logit)

Rows correspond to number of studies. Columns correspond to ranges of expected count. Points on the dashed line have equal proportion RMSE for both methods. Points indicate simulation scenarios, and are coded with two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1). Black color indicates scenarios with small heterogeneity, and red scenarios with large heterogeneity. Only a representative subset of scenarios is plotted. Note the change in scale across columns.

The diagram shows 9 scatter plots of scaled root mean squared error (RMSE) in a 3-by-3 array. Each scatter plot shows the scaled RMSE for logit-transformed data on the x-axis versus the scaled RMSE for untransformed data on the y-axis, for a number of points corresponding to different true proportions (.001, .005, .01, .05, .1) and sample-size scenarios (small, medium, large, and mixed). The rows of the array, from top to bottom, correspond to 5, 15, and 30 studies, respectively. The columns of the array, from left to right, correspond to the following ranges of expected counts: less than 1, between 1 and 5, and greater than 5.

Figure 4 Difference in RMSE between small and large heterogeneity scenarios: no transformation versus canonical transformation (logit)

Shown are all simulation scenarios (not only the “representative” ones listed in Table 9). A similar pattern is observed for the absolute value of proportion bias. The horizontal dotted line at zero is the line of no difference. Vertical lines separate scenarios by expected counts categories.

The diagram shows a scatter plot of the difference in scaled root mean squared error (RMSE) between large and small heterogeneity scenarios, plotted on the y-axis, versus expected counts, plotted on the x-axis, for logit-transformed and untransformed data.

Figure 5 Comparison of coverage between approximate methods: no transformation versus canonical transformation (logit)

Rows correspond to number of studies. Columns correspond to ranges of expected count. Points on the dashed line have equal coverage for both methods. Points indicate simulation scenarios, and are coded with two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1). Black color indicates scenarios with small heterogeneity, and red scenarios with large heterogeneity. Only a representative subset of scenarios is plotted. The solid black reference lines indicate 95 percent coverage.

The diagram shows 9 scatter plots of coverage a 3-by-3 array. Each scatter plot shows the coverage for logit-transformed data on the x-axis versus the coverage for untransformed data on the y-axis, for a number of points corresponding to different true proportions (.001, .005, .01, .05, .1) and sample-size scenarios (small, medium, large, and mixed). The rows of the array, from top to bottom, correspond to 5, 15, and 30 studies, respectively. The columns of the array, from left to right, correspond to the following ranges of expected counts: less than 1, between 1 and 5, and greater than 5.

#### No Transformation Versus Variance-Stabilizing Transformation (Arcsine Transformation)

Figure 6 and Figure 7 compare proportion bias and proportion RMSE, respectively for random effects meta-analysis on untransformed versus arcsine-transformed data. Many of the observations and explanations below are similar to those made in No Transformation Versus Canonical Transformation (Logit Transformation).

- For small expected counts (≤1), analyses based on the variance-stabilizing transformation has much smaller proportion bias and proportion RMSE than those based on untransformed data. This difference is attenuated for simulation scenarios with larger expected counts.

Analyses based on untransformed data require continuity corrections (and most often when the expected counts are ≤1). As discussed in No Transformation Versus Canonical Transformation (Logit Transformation), the net effect is a large positive bias and a large proportion RMSE. However, for arcsine transformed data, no continuity corrections are needed, and thus the proportion bias and proportion RMSE are comparatively much smaller.

- For both methods, the proportion bias and the proportion RMSE do not change dramatically with the number of studies, K.

The influence of the number of studies on proportion bias (and the proportion RMSE) is small, as in No Transformation Versus Canonical Transformation (Logit Transformation).

- For expected counts less than 1, proportion bias and proportion RMSE are not very different between scenarios with smaller and larger heterogeneity. All other things being equal, differences in proportion RMSE between smaller and larger heterogeneity scenarios are evident for expected counts larger than 1 (Figure 8; and similarly of the absolute value of proportion bias—not shown).

A likely explanation is that for small expected counts, the estimate of between study heterogeneity is very often 0 or close to 0, and this attenuates any differences between scenarios with smaller and larger simulated heterogeneity.

- Analytically, we expect the proportion bias to be negative for analyses based on both untransformed and arcsine-transformed data (See appendix). As described in No Transformation Versus Canonical Transformation (Logit Transformation), the need for continuity corrections (cc) adds an additional bias component for analyses based on untransformed data. This additional bias component can be positive, zero, or negative, for (cc)/(n_j , k_) > π_j_ , (cc)/(n_j , k_) = π_j_ , or (cc)/(n_j , k_) < π_j_ , respectively.
- For expected counts ≥5, proportion bias is slightly better on the arcsine scale under small amounts of heterogeneity, but no clear trend is evident for RMSE. For expected counts between 1 and 5, the two methods are comparable for proportion bias, but the arcsine scale may have a bit higher RMSE.

Figure 6 Comparison of proportion bias between approximate methods: no transformation versus arcsine-transformation

Rows correspond to number of studies. Columns correspond to ranges of expected count. Points on the dashed line have equal proportion bias for both methods. Points indicate simulation scenarios, and are coded with two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1). Black color indicates scenarios with small heterogeneity, and red scenarios with large heterogeneity. Only a representative subset of scenarios is plotted. The solid black reference lines indicate 0 bias. Note the change in scale across columns.

The diagram shows 9 scatter plots of scaled bias in a 3-by-3 array. Each scatter plot shows the scaled bias for arcsine-transformed data on the x-axis versus the scaled bias for untransformed data on the y-axis, for a number of points corresponding to different true proportions (.001, .005, .01, .05, .1) and sample-size scenarios (small, medium, large, and mixed). The rows of the array, from top to bottom, correspond to 5, 15, and 30 studies, respectively. The columns of the array, from left to right, correspond to the following ranges of expected counts: less than 1, between 1 and 5, and greater than 5.

Figure 7 Comparison of proportion RMSE between approximate methods: no transformation versus variance stabilizing (arcsine) transformation

Rows correspond to number of studies. Columns correspond to ranges of expected count. Points on the dashed line have equal proportion RMSE for both methods. Points indicate simulation scenarios, and are coded with two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1). Black color indicates scenarios with small heterogeneity, and red scenarios with large heterogeneity. Only a representative subset of scenarios is plotted. Note the change in scale across columns.

The diagram shows 9 scatter plots of scaled root mean squared error (RMSE) in a 3-by-3 array. Each scatter plot shows the scaled RMSE for arcsine-transformed data on the x-axis versus the scaled RMSE for untransformed data on the y-axis, for a number of points corresponding to different true proportions (.001, .005, .01, .05, .1) and sample-size scenarios (small, medium, large, and mixed). The rows of the array, from top to bottom, correspond to 5, 15, and 30 studies, respectively. The columns of the array, from left to right, correspond to the following ranges of expected counts: less than 1, between 1 and 5, and greater than 5.

Figure 8 Difference in RMSE between small and large heterogeneity scenarios: no transformation versus variance stabilizing (arcsine) transformation

Shown are all simulation scenarios (not only the “representative” ones listed in Table 9). A similar pattern is observed for the absolute value of proportion bias. The horizontal dotted line at zero is the line of no difference. Vertical lines separate scenarios by expected counts categories.

The diagram shows a scatter plot of the difference in scaled root mean squared error (RMSE) between large and small heterogeneity scenarios, plotted on the y-axis, versus expected counts, plotted on the x-axis, for arcsine-transformed and untransformed data.

For both methods, coverage is better when the expected count is at least 5 (Figure 9), compared to ≤ 1 or between 1 and 5.

The normal is a better approximation to the binomial as the expected counts increase above 5.

- For expected counts ≥5, coverage is better for the variance stabilizing transformation compared to the untransformed data.
- Coverage appears to become worse with increasing K, and more so for scenarios where heterogeneity is large. This is more evident for expected counts between 1 and 5.

We have found no explanation for this pattern.

Figure 9 Comparison of coverage between approximate methods: no transformation versus variance stabilizing (arcsine) transformation

Rows correspond to number of studies. Columns correspond to ranges of expected count. Points on the dashed line have equal coverage for both methods. Points indicate simulation scenarios, and are coded with two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1). Black color indicates scenarios with small heterogeneity, and red scenarios with large heterogeneity. Only a representative subset of scenarios is plotted. The solid black reference lines indicate 95 percent coverage.

The diagram shows 9 scatter plots of coverage in a 3-by-3 array. Each scatter plot shows the coverage for arcsine-transformed data on the x-axis versus the coverage for untransformed data on the y-axis, for a number of points corresponding to different true proportions (.001, .005, .01, .05, .1) and sample-size scenarios (small, medium, large, and mixed). The rows of the array, from top to bottom, correspond to 5, 15, and 30 studies, respectively. The columns of the array, from left to right, correspond to the following ranges of expected counts: less than 1, between 1 and 5, and greater than 5.

#### Canonical (Logit) Versus Variance-Stabilizing (Arcsine) Transformation

Figure 10 and Figure 11 compare proportion bias and proportion RMSE, respectively for random effects meta-analysis on logit-transformed versus arcsine-transformed data. Many of the observations and explanations below are similar to those made in two sections: No Transformation Versus Canonical Transformation (Logit Transformation) and No Transformation Versus Variance-Stabilizing Transformation (Arcsine Transformation).

- For small expected counts (≤1), analyses based on arcsine transformed data have much smaller proportion bias and proportion RMSE compared to those based on logit-transformed data. For larger expected counts, the differences are very small (most points in Figure 10 and Figure 11 are on the diagonal).

Analyses based on logit-transformed data require continuity corrections (and most often when the expected counts are ≤1). As discussed in No Transformation Versus Canonical Transformation (Logit Transformation), the net effect is a large positive bias and a large proportion RMSE. However, for arcsine transformed data (No Transformation Versus Variance-Stabilizing Transformation [Arcsine Transformation]), no continuity corrections are needed, and thus the proportion bias and proportion RMSE are smaller.

- For both methods, the proportion bias and the proportion RMSE do not change dramatically with the number of studies, K.

The influence of the number of studies on proportion bias (and the proportion RMSE) is small, as in previous sections.

- For expected counts less than 1, proportion bias and proportion RMSE are not very different between scenarios with smaller and larger heterogeneity. All other things being equal, differences in proportion RMSE between smaller and larger heterogeneity scenarios are evident for expected counts larger than 1 (Figure 12; and similarly for the absolute value of proportion bias – not shown).

For small expected counts, the estimate of between study heterogeneity is very often 0 or close to 0, and this attenuates any differences between scenarios with smaller and larger simulated heterogeneity.

- Analytically, we expect the proportion bias to be negative for analyses based on arcsine-transformed data, and positive for analyses based on logit-transformed data (See appendix). As described in No Transformation Versus Canonical Transformation (Logit Transformation), the need for continuity corrections (cc) adds an additional bias component for analyses based on logit-transformed data. This additional bias component can be positive, zero, or negative, for (cc)/(n_j , k_) > π_j_ , (cc)/(n_j , k_) = π_j_ , or (cc)/(n_j , k_) < π_j_ , respectively.

Figure 10 Comparison of proportion bias between approximate methods: canonical (logit) versus variance stabilizing (arcsine) transformation

Rows correspond to number of studies. Columns correspond to ranges of expected count. Points on the dashed line have equal proportion bias for both methods. Points indicate simulation scenarios, and are coded with two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1). Black color indicates scenarios with small heterogeneity, and red scenarios with large heterogeneity. Only a representative subset of scenarios is plotted. The solid black reference lines indicate 0 bias. Note the change in scale across columns.

The diagram shows 9 scatter plots of scaled bias in a 3-by-3 array. Each scatter plot shows the scaled bias for arcsine-transformed data on the x-axis versus the scaled bias for logit-transformed data on the y-axis, for a number of points corresponding to different true proportions (.001, .005, .01, .05, .1) and sample-size scenarios (small, medium, large, and mixed). The rows of the array, from top to bottom, correspond to 5, 15, and 30 studies, respectively. The columns of the array, from left to right, correspond to the following ranges of expected counts: less than 1, between 1 and 5, and greater than 5.

Figure 11 Comparison of proportion RMSE between approximate methods: canonical (logit) versus variance stabilizing (arcsine) transformation

Rows correspond to number of studies. Columns correspond to ranges of expected count. Points on the dashed line have equal proportion RMSE for both methods. Points indicate simulation scenarios, and are coded with two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1). Black color indicates scenarios with small heterogeneity, and red scenarios with large heterogeneity. Only a representative subset of scenarios is plotted. Note the change in scale across columns.

The diagram shows 9 scatter plots of scaled root mean squared error (RMSE) in a 3-by-3 array. Each scatter plot shows the scaled RMSE for arcsine-transformed data on the x-axis versus the scaled RMSE for logit-transformed data on the y-axis, for a number of points corresponding to different true proportions (.001, .005, .01, .05, .1) and sample-size scenarios (small, medium, large, and mixed). The rows of the array, from top to bottom, correspond to 5, 15, and 30 studies, respectively. The columns of the array, from left to right, correspond to the following ranges of expected counts: less than 1, between 1 and 5, and greater than 5.

Figure 12 Difference in RMSE between small and large heterogeneity scenarios: canonical (logit) versus variance stabilizing (arcsine) transformation

Shown are all simulation scenarios (not only the “representative” ones listed in Table 9). A similar pattern is observed for the absolute value of proportion bias. The horizontal dotted line at zero is the line of no difference. Vertical lines separate scenarios by expected counts categories.

The diagram shows a scatter plot of the difference in scaled root mean squared error (RMSE) between large and small heterogeneity scenarios, plotted on the y-axis, versus expected counts, plotted on the x-axis, for arcsine-transformed and logit-transformed data.

For both methods, coverage is better when the expected count is at least 5 (Figure 13), compared to expected counts of 1 or less, or between 1 and 5.

The normal distribution approximates the binomial better as expected counts increase above 5.

- For expected counts ≥5, coverage is similar for both methods.
- For expected counts ≤5, analyses based on the arcsine transformation have better coverage.

For small expected counts, continuity corrections are often needed for logit-transformed data. The large positive bias (associated with the use of the continuity corrections) can displace the point estimate sufficiently to result in 0 percent coverage.

- For expected counts between 1 and 5, coverage appears to become worse with increasing K, and more so for scenarios where heterogeneity is large.

We have found no explanation for this pattern.

Figure 13 Comparison of coverage between approximate methods: canonical (logit) versus variance stabilizing (arcsine) transformation

Rows correspond to number of studies. Columns correspond to ranges of expected count. Points on the dashed line have equal coverage for both methods. Points indicate simulation scenarios, and are coded with two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1). Black color indicates scenarios with small heterogeneity, and red scenarios with large heterogeneity. Only a representative subset of scenarios is plotted. The solid black reference lines indicate 95 percent coverage.

The diagram shows 9 scatter plots of coverage in a 3-by-3 array. Each scatter plot shows the coverage for arcsine-transformed data on the x-axis versus the coverage for logit-transformed data on the y-axis, for a number of points corresponding to different true proportions (.001, .005, .01, .05, .1) and sample-size scenarios (small, medium, large, and mixed). The rows of the array, from top to bottom, correspond to 5, 15, and 30 studies, respectively. The columns of the array, from left to right, correspond to the following ranges of expected counts: less than 1, between 1 and 5, and greater than 5.

#### Effect of the Correction Factor for Zero-Event Studies

The approximate methods for untransformed and logit-transformed data apply a correction factor to adjust the estimated proportion for zero-event studies. The correction factor is arbitrary, in that it is not selected with a procedure that proposes a unique value. We report results using a continuity correction of 0.5, a very commonly used value.

As discussed in the Methods section, the correction factor introduces a bias that depends on the size of the correction factor and the sample size of the study.

Figure 14 shows the mean summary proportion for fixed effects inverse variance meta-analyses with 15 studies with average sample size equal to 115 for various values of the correction factor, assuming a true proportion of 0.010 and no between-study heterogeneity. Approximately 1/3 of the simulated studies have 0 events. Note the estimated proportion is less than the true proportion for small values of the correction factor, and increases as the correction factor gets larger. For some value of the correction factor (in this case 1), the estimated proportion will be exactly the true proportion, but this is of no use in practice since the “optimal” value of the correction factor depends on the true proportion and sample sizes.

Figure 14 Bias induced by correction factors in fixed effects meta-analysis of untransformed data

The figure shows a graph of the estimated proportion (using a correction factor) when there are zero events, as a function of the size of the correction factor. The graphs shows that there is a negative bias for small correction factors and a positive bias for large correction factors.

Since the correction factor is unrelated to the true proportion, the overall meta-analysis estimate is skewed towards the adjusted estimate, resulting in greater absolute bias and RMSE, and poorer coverage. This typically occurs for small true proportions and sample sizes.

### Pairwise Comparisons Between Approximate and Discrete Likelihood Methods for Random Effects Meta-Analysis

For random effects meta-analysis, results based on the binomial likelihood (exact method) have proportion bias and proportion RMSE closer to zero and coverage probabilities closer to 95 percent, compared to those based on the approximate methods across a wide range of scenarios, as explained below.

Therefore, we recommend the discrete likelihood method for random effects meta-analysis over approximate methods.

#### Approximate Method With No Transformation Versus Discrete Likelihood Method

Figure 15 compares the proportion bias for random effects meta-analysis using the approximate method with untransformed data versus the discrete likelihood method that maximizes the binomial likelihood.

Figure 15 Comparison of proportion bias: approximate method (no transformation) versus discrete likelihood

Rows correspond to number of studies. Columns correspond to ranges of expected count. Points on the dashed line have equal proportion bias for both methods. Points indicate simulation scenarios, and are coded with two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1). Black color indicates scenarios with small heterogeneity, and red scenarios with large heterogeneity. Only a representative subset of scenarios is plotted. The solid black reference lines indicate 0 bias. Note the change in scale across columns.

The diagram shows 9 scatter plots of scaled bias in a 3-by-3 array. Each scatter plot shows the scaled bias for the discrete likelihood method on the x-axis versus the scaled bias for untransformed data on the y-axis, for a number of points corresponding to different true proportions (.001, .005, .01, .05, .1) and sample-size scenarios (small, medium, large, and mixed). The rows of the array, from top to bottom, correspond to 5, 15, and 30 studies, respectively. The columns of the array, from left to right, correspond to the following ranges of expected counts: less than 1, between 1 and 5, and greater than 5.

Figure 16 depicts proportion RMSE. Based on the two figures, we make the following observations:

- The absolute proportion bias (deviation from 0) is generally smaller for the discrete likelihood method compared to the approximate method using untransformed data, particularly when expected counts ≤1.

Meta-analyses with approximate methods and untransformed data require continuity corrections (and most often when the expected counts are ≤1). As discussed in No Transformation Versus Canonical Transformation (Logit Transformation), the net effect is a large positive bias and a large proportion RMSE. Continuity corrections are not needed for the discrete likelihood method.

- For meta-analyses with 15 or 30 studies and expected counts larger than 1, the proportion bias of the discrete likelihood binomial method is approximately constant at each level of heterogeneity. For large heterogeneity, the proportion bias is approximately -10 percent of the respective true proportion, while for small heterogeneity, it is approximately 0. If the true proportion is exactly 0.50, the proportion bias is approximately 0.

We have no definitive explanation for the approximately constant proportion bias of -10 percent, which is observed across all proportions when heterogeneity is large, and the true summary proportion is different than 0.50. A plausible conjecture is based on the observation that the random effects discrete likelihood methods assume a logit-normal distribution of the true proportions across studies. A range of e.g., 0.10 in the proportion scale corresponds to vastly different ranges in the logit scale, depending on its location. For example the interval [0.01, 0.11] in the proportion scale corresponds to a length of [-4.60, -2.09] in the logit scale, but the interval [0.45, 0.55] corresponds to the much narrower [-0.20, 0.20] in the logit scale. The further away a given interval is located from 0.50 in the proportion scale, the more it expands in the logit scale. “Averaging” in the logit scale will therefore result in a negative bias in the proportion scale when the true mean is less than 0.50; no bias if the true mean is 0.50, and (by symmetry) a positive bias if the true mean is more than 0.50.

- When all studies have large sample sizes and the heterogeneity is large, the approximate method with untransformed data has proportion bias closer to 0 compared to the discrete likelihood method. (See points L4 and L5 in red font on the rightmost column in Figure 15).

This occurs because for large heterogeneity and expected counts ≥5 the discrete likelihood methods have a proportion bias of approximately -10 percent, regardless of the sample sizes of the studies. In these same scenarios, the normal approximation to the binomial is good enough to result in better proportion bias for the approximate compared to the discrete likelihood methods.

- For expected counts ≤1, primarily, the proportion bias of both the discrete likelihood and the approximate methods is positive. For larger expected counts the proportion bias for both methods becomes negative.

For the approximate methods, the explanation has been given in No Transformation Versus Canonical Transformation (Logit Transformation): Analytically we expect the bias to be negative. However, when the expected count is ≤1, studies will often have 0 events, and a continuity correction factor, cc, is needed. This additional bias component can be positive, zero, or negative, for (cc)/(n_j , k_) > π_j_ , (cc)/(n_j , k_) = π_j_ , or (cc)/(n_j , k_) < π_j_ , respectively. For the discrete likelihood method, the explanation is much simpler. When all studies have a 0 numerator, the discrete likelihood method (random effects logistic regression) fails to converge. Because simulations that fail to converge do not contribute to the calculations of proportion bias, proportion RMSE and coverage, these metrics should be interpreted with caution.

- Proportion RMSE is generally lower for the discrete likelihood method. The differences are largest for small expected counts.
  For expected counts less than 1, proportion bias and proportion RMSE are not very different between scenarios with smaller and larger heterogeneity. All other things being equal, differences in proportion RMSE between smaller and larger heterogeneity scenarios are evident for expected counts larger than 1 (Figure 17; and similarly of the absolute value of proportion bias – not shown).
- Proportion RMSE is larger for large amounts of heterogeneity.

Large amounts of heterogeneity increases variance, one of the components of mean squared error. When there is a lot of data, variability decreases and bias tends to dominate the mean squared error.

- The coverage of the discrete likelihood binomial method (Figure 18) is much closer to the desired value of 95 percent than that of the approximate method on untransformed data. This is particularly noticeable for K=15 and 30 studies.

The normal approximation to the binomial is much better for large expected counts compared to smaller expected counts. Further, for small expected counts, numerators with zero counts are common and continuity corrections are needed for the approximate method. Thus, coverage is suboptimal with the approximate method. See these two sections: No Transformation Versus Canonical Transformation (Logit Transformation) and No Transformation Versus Variance-Stabilizing Transformation (Arcsine Transformation).

Figure 16 Comparison of proportion RMSE: approximate method (no transformation) versus discrete likelihood

Rows correspond to number of studies. Columns correspond to ranges of expected count. Points on the dashed line have equal proportion RMSE for both methods. Points indicate simulation scenarios, and are coded with two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1). Black color indicates scenarios with small heterogeneity, and red scenarios with large heterogeneity. Only a representative subset of scenarios is plotted. Note the change in scale across columns.

The diagram shows 9 scatter plots of scaled root mean squared error (RMSE) in a 3-by-3 array. Each scatter plot shows the scaled RMSE for the discrete likelihood method on the x-axis versus the scaled RMSE for untransformed data on the y-axis, for a number of points corresponding to different true proportions (.001, .005, .01, .05, .1) and sample-size scenarios (small, medium, large, and mixed). The rows of the array, from top to bottom, correspond to 5, 15, and 30 studies, respectively. The columns of the array, from left to right, correspond to the following ranges of expected counts: less than 1, between 1 and 5, and greater than 5.

Figure 17 Difference in RMSE between small and large heterogeneity scenarios for analyses using the approximate method (no transformation) and the discrete likelihood method

Shown are all simulation scenarios (not only the “representative” ones listed in Table 9). A similar pattern is observed for the absolute value of proportion bias. The horizontal dotted line at zero is the line of no difference. Vertical lines separate scenarios by expected counts categories.

The diagram shows a scatter plot of the difference in scaled root mean squared error (RMSE) between large and small heterogeneity scenarios, plotted on the y-axis, versus expected counts, plotted on the x-axis, for the discrete likelihood method and untransformed data.

Figure 18 Comparison of coverage: approximate method (no transformation) versus discrete likelihood

Rows correspond to number of studies. Columns correspond to ranges of expected count. Points on the dashed line have equal coverage for both methods. Points indicate simulation scenarios, and are coded with two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1). Black color indicates scenarios with small heterogeneity, and red scenarios with large heterogeneity. Only a representative subset of scenarios is plotted. The solid black reference lines indicate 95 percent coverage.

The diagram shows 9 scatter plots of coverage in a 3-by-3 array. Each scatter plot shows the coverage for the discrete likelihood method on the x-axis versus the coverage for untransformed data on the y-axis, for a number of points corresponding to different true proportions (.001, .005, .01, .05, .1) and sample-size scenarios (small, medium, large, and mixed). The rows of the array, from top to bottom, correspond to 5, 15, and 30 studies, respectively. The columns of the array, from left to right, correspond to the following ranges of expected counts: less than 1, between 1 and 5, and greater than 5.

#### Approximate Method With Logit Transformation Versus Discrete Likelihood Method

Figure 19 compares proportion bias for random-effects meta-analysis using the approximate method on logit-transformed data versus the discrete likelihood binomial method.

Figure 19 Comparison of proportion bias: approximate method (logit transformation) versus discrete likelihood

Rows correspond to number of studies. Columns correspond to ranges of expected count. Points on the dashed line have equal proportion bias for both methods. Points indicate simulation scenarios, and are coded with two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1). Black color indicates scenarios with small heterogeneity, and red scenarios with large heterogeneity. Only a representative subset of scenarios is plotted. The solid black reference lines indicate 0 bias. Note the change in scale across columns.

The diagram shows 9 scatter plots of scaled bias in a 3-by-3 array. Each scatter plot shows the scaled bias for the discrete likelihood method on the x-axis versus the scaled bias for logit-transformed data on the y-axis, for a number of points corresponding to different true proportions (.001, .005, .01, .05, .1) and sample-size scenarios (small, medium, large, and mixed). The rows of the array, from top to bottom, correspond to 5, 15, and 30 studies, respectively. The columns of the array, from left to right, correspond to the following ranges of expected counts: less than 1, between 1 and 5, and greater than 5.

Figure 20 depicts the proportion RMSE. We make the following observations:

- The absolute proportion bias (deviation from 0) is generally smaller for the discrete likelihood method compared to the approximate method on logit transformed data. This is more profound for expected counts ≤5.

Meta-analyses with approximate methods and untransformed data require continuity corrections (and most often when the expected counts are ≤1). As discussed in No Transformation Versus Canonical Transformation (Logit Transformation), the net effect is a large positive bias and a large proportion RMSE. Continuity corrections are not needed for the discrete likelihood method.

- As discussed in Approximate Method With No Transformation Versus Discrete Likelihood Method, for meta-analyses with 15 or 30 studies and expected counts larger than 1, the proportion bias of the discrete likelihood binomial method is approximately constant at each level of heterogeneity. For large heterogeneity, the proportion bias is approximately -10 percent of the respective true proportion, while for small heterogeneity, it is approximately 0. If the true proportion is exactly 0.50, the proportion bias is approximately 0.

We have no definitive explanation for the approximately constant proportion bias of -10 percent, which is observed across all proportions when heterogeneity is large, and the true summary proportion is different than 0.50. A plausible conjecture is based on the observation that the random effects discrete likelihood methods assume a logit-normal distribution of the true proportions across studies. A range of e.g., 0.10 in the proportion scale corresponds to vastly different ranges in the logit scale, depending on its location. For example the interval [0.01, 0.11] in the proportion scale corresponds to a length of [-4.60, -2.09] in the logit scale, but the interval [0.45, 0.55] corresponds to the much narrower [-0.20, 0.20] in the logit scale. The further away a given interval is located from 0.50 in the proportion scale, the more it expands in the logit scale. “Averaging” in the logit scale will therefore result in a negative bias in the proportion scale when the true mean is less than 0.50; no bias if the true mean is 0.50, and (by symmetry) a positive bias if the true mean is more than 0.50. The finding that for large expected counts (scenarios L4 and L5) the logit-transformed bias approaches that of the discrete likelihood method supports this conjecture.

- For expected counts ≤1, primarily, the proportion bias for the discrete likelihood method is positive. It becomes negative for larger expected counts.

As described in Approximate Method With No Transformation Versus Discrete Likelihood Method, when all studies have a 0 numerator, the discrete likelihood method (random effects logistic regression) fails to converge. Because simulations that fail to converge do not contribute to the calculations of proportion bias, proportion RMSE and coverage, these metrics are biased.

- Proportion RMSE is generally lower for the discrete likelihood method. The differences are largest for small expected counts and small when expected counts ≥ 5.

For expected counts less than 1, the proportion bias and the proportion RMSE are not very different between scenarios with smaller and larger heterogeneity. All other things being equal, differences in proportion RMSE between smaller and larger heterogeneity scenarios are evident for expected counts larger than 1 (Figure 21; and similarly for the absolute value of proportion bias—not shown).

Figure 20 Comparison of proportion RMSE: approximate method (logit transformation) versus discrete likelihood

Rows correspond to number of studies. Columns correspond to ranges of expected count. Points on the dashed line have equal proportion RMSE for both methods. Points indicate simulation scenarios, and are coded with two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1). Black color indicates scenarios with small heterogeneity, and red scenarios with large heterogeneity. Only a representative subset of scenarios is plotted. Note the change in scale across columns.

The diagram shows 9 scatter plots of scaled root mean squared error (RMSE) in a 3-by-3 array. Each scatter plot shows the scaled RMSE for the discrete likelihood method on the x-axis versus the scaled RMSE for logit-transformed data on the y-axis, for a number of points corresponding to different true proportions (.001, .005, .01, .05, .1) and sample-size scenarios (small, medium, large, and mixed). The rows of the array, from top to bottom, correspond to 5, 15, and 30 studies, respectively. The columns of the array, from left to right, correspond to the following ranges of expected counts: less than 1, between 1 and 5, and greater than 5.

Figure 21 Difference in RMSE between small and large heterogeneity scenarios for analyses using the approximate methods (logit transformation) and the discrete likelihood method

Shown are all simulation scenarios (not only the “representative” ones listed in Table 9). A similar pattern is observed for the absolute value of proportion bias. The horizontal dotted line at zero is the line of no difference. Vertical lines separate scenarios by expected counts categories.

The diagram shows a scatter plot of the difference in scaled root mean squared error (RMSE) between large and small heterogeneity scenarios, plotted on the y-axis, versus expected counts, plotted on the x-axis, for the discrete likelihood method and logit-transformed data.

Figure 22 shows coverage probabilities.

- The coverage of the discrete likelihood binomial method is much closer to the desired value of 95 percent than that of the approximate method on logit-transformed data. This is particularly noticeable for K=15 and 30 studies.

The normal approximation to the binomial is much better for large expected counts compared to smaller expected counts. Further, for small expected counts, 0 numerators are common and continuity corrections are needed for the approximate method. Thus, coverage is suboptimal with the approximate method. See also two sections: No Transformation Versus Canonical Transformation (Logit Transformation) and No Transformation Versus Variance-Stabilizing Transformation (Arcsine Transformation).

Figure 22 Comparison of coverage: approximate method (logit transformation) versus discrete likelihood

Rows correspond to number of studies. Columns correspond to ranges of expected count. Points on the dashed line have equal coverage for both methods. Points indicate simulation scenarios, and are coded with two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1). Black color indicates scenarios with small heterogeneity, and red scenarios with large heterogeneity. Only a representative subset of scenarios is plotted. The solid black reference lines indicate 95 percent coverage.

The diagram shows 9 scatter plots of coverage in a 3-by-3 array. Each scatter plot shows the coverage for the discrete likelihood method on the x-axis versus the coverage for logit-transformed data on the y-axis, for a number of points corresponding to different true proportions (.001, .005, .01, .05, .1) and sample-size scenarios (small, medium, large, and mixed). The rows of the array, from top to bottom, correspond to 5, 15, and 30 studies, respectively. The columns of the array, from left to right, correspond to the following ranges of expected counts: less than 1, between 1 and 5, and greater than 5.

#### Approximate Method With Arcsine Transformation Versus Discrete Likelihood Binomial Method

Figure 23 compares proportion bias for random-effects meta-analysis using the approximate method with the variance stabilizing (arcsine) transformation versus the discrete likelihood method. Figure 24 depicts the proportion RMSE. We make the following observations:

- The absolute proportion bias (deviation from 0) is generally smaller for the discrete likelihood method compared to the approximate method on arcsine transformed data. This is more pronounced for expected counts ≤5.

The normal approximation to the binomial becomes better when the expected counts are >5 compared with smaller expected counts.

- As discussed in Approximate Method With No Transformation Versus Discrete Likelihood Method, for meta-analyses with 15 or 30 studies and expected counts larger than 1, the proportion bias of the discrete likelihood binomial method is approximately constant at each level of heterogeneity. For large heterogeneity, the proportion bias is approximately -10 percent of the respective true proportion, while for small heterogeneity, it is approximately 0. If the true proportion is exactly 0.50, the proportion bias is approximately 0.

We have no definitive explanation for the approximately constant proportion bias of -10 percent, which is observed across all proportions when heterogeneity is large, and the true summary proportion is different than 0.50. A plausible conjecture is based on the observation that the random effects discrete likelihood methods assume a logit-normal distribution of the true proportions across studies. A range of e.g., 0.10 in the proportion scale corresponds to vastly different ranges in the logit scale, depending on its location. For example the interval [0.01, 0.11] in the proportion scale corresponds to a length of [-4.60, -2.09] in the logit scale, but the interval [0.45, 0.55] corresponds to the much narrower [-0.20, 0.20] in the logit scale. The further away a given interval is located from 0.50 in the proportion scale, the more it expands in the logit scale. “Averaging” in the logit scale will therefore result in a negative bias in the proportion scale when the true mean is less than 0.50; no bias if the true mean is 0.50, and (by symmetry) a positive bias if the true mean is more than 0.50. The finding that for large expected counts (scenarios L4 and L5) the logit-transformed bias approaches that of the discrete likelihood method supports this conjecture.

- RMSE is higher with the arcsine method for expected counts between 1 and 5.
- For expected counts less than 1, the proportion bias and the proportion RMSE differ little between scenarios with smaller and larger heterogeneity.
- All other things being equal, differences in proportion RMSE between smaller and larger heterogeneity scenarios are evident for expected counts larger than 1 (Figure 25; and similarly of the absolute value of proportion bias—not shown). RMSE is larger with more heterogeneity.

Figure 23 Comparison of proportion bias: approximate method (arcsine transformation) versus discrete likelihood

Rows correspond to number of studies. Columns correspond to ranges of expected count. Points on the dashed line have equal proportion bias for both methods. Points indicate simulation scenarios, and are coded with two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1). Black color indicates scenarios with small heterogeneity, and red scenarios with large heterogeneity. Only a representative subset of scenarios is plotted. The solid black reference lines indicate 0 bias. Note the change in scale across columns.

The diagram shows 9 scatter plots of scaled bias in a 3-by-3 array. Each scatter plot shows the scaled bias for the discrete likelihood method on the x-axis versus the scaled bias for arcsine-transformed data on the y-axis, for a number of points corresponding to different true proportions (.001, .005, .01, .05, .1) and sample-size scenarios (small, medium, large, and mixed). The rows of the array, from top to bottom, correspond to 5, 15, and 30 studies, respectively. The columns of the array, from left to right, correspond to the following ranges of expected counts: less than 1, between 1 and 5, and greater than 5.

Figure 24 Comparison of proportion RMSE: approximate method (arcsine transformation) versus discrete likelihood method

Rows correspond to number of studies. Columns correspond to ranges of expected count. Points on the dashed line have equal proportion RMSE for both methods. Points indicate simulation scenarios, and are coded with two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1). Black color indicates scenarios with small heterogeneity, and red scenarios with large heterogeneity. Only a representative subset of scenarios is plotted. Note the change in scale across columns.

The diagram shows 9 scatter plots of scaled root mean squared error (RMSE) in a 3-by-3 array. Each scatter plot shows the scaled RMSE for the discrete likelihood method on the x-axis versus the scaled RMSE for arcsine-transformed data on the y-axis, for a number of points corresponding to different true proportions (.001, .005, .01, .05, .1) and sample-size scenarios (small, medium, large, and mixed). The rows of the array, from top to bottom, correspond to 5, 15, and 30 studies, respectively. The columns of the array, from left to right, correspond to the following ranges of expected counts: less than 1, between 1 and 5, and greater than 5.

Figure 25 Difference in RMSE between small and large heterogeneity scenarios for analyses using approximate methods (arcsine transformation) and the discrete likelihood method

Shown are all simulation scenarios (not only the “representative” ones listed in Table 9). A similar pattern is observed for the absolute value of proportion bias. The horizontal dotted line at zero is the line of no difference. Vertical lines separate scenarios by expected counts categories.

The diagram shows a scatter plot of the difference in scaled root mean squared error (RMSE) between large and small heterogeneity scenarios, plotted on the y-axis, versus expected counts, plotted on the x-axis, for the discrete likelihood method and arcsine-transformed data.

Figure 26 shows coverage probabilities.

- For expected counts above 5, the coverage probabilities are very similar for the approximate methods on arcsine-transformed data and the discrete likelihood methods.
- Coverage is better under scenarios with less heterogeneity
- With large amounts of heterogeneity, both methods have inadequate coverage
- For expected counts less than 5, the coverage of the discrete likelihood binomial method is much closer to the desired value of 95 percent than that of the approximate method on arcsine-transformed data.

Figure 26 Comparison of coverage: approximate method (arcsine transformation) versus discrete likelihood method

Rows correspond to number of studies. Columns correspond to ranges of expected count. Points on the dashed line have equal coverage for both methods. Points indicate simulation scenarios, and are coded with two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1). Black color indicates scenarios with small heterogeneity, and red scenarios with large heterogeneity. Only a representative subset of scenarios is plotted. The solid black reference lines indicate 95 percent coverage.

The diagram shows 9 scatter plots of coverage in a 3-by-3 array. Each scatter plot shows the coverage for the discrete likelihood method on the x-axis versus the coverage for arcsine-transformed data on the y-axis, for a number of points corresponding to different true proportions (.001, .005, .01, .05, .1) and sample-size scenarios (small, medium, large, and mixed). The rows of the array, from top to bottom, correspond to 5, 15, and 30 studies, respectively. The columns of the array, from left to right, correspond to the following ranges of expected counts: less than 1, between 1 and 5, and greater than 5.

### Comparison Between Fixed and Random-Effects Discrete Likelihood Binomial Methods

Most meta-analyses use random effects methods. For random effects meta-analysis, discrete likelihood methods have less bias, smaller RMSE, and better coverage probabilities compared to approximate methods for a large range of simulation scenarios (See two sections: Pairwise Comparisons Among Approximate Methods—Random Effects Meta-Analysis and Pairwise Comparisons Between Approximate and Discrete Likelihood Methods for Random Effects Meta-Analysis), and are thus preferable.

Here we present comparisons between fixed and random effects meta-analysis using the discrete likelihood methods. Figure 27 compares the proportion bias and Figure 28 the proportion RMSE with fixed versus random effects analyses. We make the following observations:

- Results based on the fixed-effect discrete likelihood binomial method have smaller absolute proportion bias than results based on the random-effects discrete likelihood binomial method, particularly for data with high heterogeneity—see Figure 27, the whole left column.

The fixed effects estimator with the discrete likelihood method is an unbiased estimator. Pairwise Comparisons Between Approximate and Discrete Likelihood Methods for Random Effects Meta-Analysis discussed the bias observed with the random effects methods: it is constant at each level of heterogeneity, and is small (around 0 percent) for smaller heterogeneity, and approximately -10 percent for larger heterogeneity scenarios when the true proportion is not 0.50.

- The proportion RMSE is approximately the same for the two methods—see Figure 28.

When the expected counts are small, it common to have meta-analyses where all studies have zero counts in the numerator. In such cases, the discrete likelihood method (random effects logistic regression) fails to converge. Because simulations that fail to converge do not contribute to the calculations of proportion bias, proportion RMSE and coverage, these metrics should be interpreted with caution.

- The random-effects discrete likelihood method has better coverage than the fixed-effect method, particularly for data with expected counts at least 1—see Figure 29.

Fixed effects analyses assume no heterogeneity. Random effects analyses estimate between-study heterogeneity and incorporate it in the calculations, resulting in wider confidence intervals compared with fixed effects analyses. Therefore, coverage is better with random effects models when the data have heterogeneity.

- The random-effects discrete likelihood method has only about 80 percent coverage when the expected counts are ≥ 5 and there is large heterogeneity.

The undercoverage results from the bias exhibited by the random effects discrete likelihood method.

Figure 27 Comparison of proportion bias: fixed versus random effects with the discrete likelihood method

Rows correspond to number of studies. Columns correspond to ranges of expected count. Points on the dashed line have equal proportion bias for both methods. Points indicate simulation scenarios, and are coded with two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1). Black color indicates scenarios with small heterogeneity, and red scenarios with large heterogeneity. Only a representative subset of scenarios is plotted. The solid black reference lines indicate 0 bias. Note the change in scale across columns.

The diagram shows 9 scatter plots of scaled bias in a 3-by-3 array. Each scatter plot shows the scaled bias for the fixed-effect discrete likelihood method on the x-axis versus the scaled bias for the random-effects discrete likelihood method on the y-axis, for a number of points corresponding to different true proportions (.001, .005, .01, .05, .1) and sample-size scenarios (small, medium, large, and mixed). The rows of the array, from top to bottom, correspond to 5, 15, and 30 studies, respectively. The columns of the array, from left to right, correspond to the following ranges of expected counts: less than 1, between 1 and 5, and greater than 5.

Figure 28 Comparison of proportion RMSE: fixed versus random effects with the discrete likelihood method

Rows correspond to number of studies. Columns correspond to ranges of expected count. Points on the dashed line have equal proportion RMSE for both methods. Points indicate simulation scenarios, and are coded with two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1). Black color indicates scenarios with small heterogeneity, and red scenarios with large heterogeneity. Only a representative subset of scenarios is plotted. Note the change in scale across columns.

The diagram shows 9 scatter plots of scaled RMSE in a 3-by-3 array. Each scatter plot shows the scaled RMSE for the fixed-effect discrete likelihood method on the x-axis versus the scaled RMSE for the random-effects discrete likelihood method on the y-axis, for a number of points corresponding to different true proportions (.001, .005, .01, .05, .1) and sample-size scenarios (small, medium, large, and mixed). The rows of the array, from top to bottom, correspond to 5, 15, and 30 studies, respectively. The columns of the array, from left to right, correspond to the following ranges of expected counts: less than 1, between 1 and 5, and greater than 5.

Figure 29 Comparison of coverage: fixed versus random effects with the discrete likelihood method

Rows correspond to number of studies. Columns correspond to ranges of expected count. Points on the dashed line have equal coverage for both methods. Points indicate simulation scenarios, and are coded with two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1). Black color indicates scenarios with small heterogeneity, and red scenarios with large heterogeneity. Only a representative subset of scenarios is plotted. The solid black reference lines indicate 95 percent coverage.

The diagram shows 9 scatter plots of coverage in a 3-by-3 array. Each scatter plot shows the coverage for the fixed-effect discrete likelihood method on the x-axis versus the coverage for the random-effects discrete likelihood method on the y-axis, for a number of points corresponding to different true proportions (.001, .005, .01, .05, .1) and sample-size scenarios (small, medium, large, and mixed). The rows of the array, from top to bottom, correspond to 5, 15, and 30 studies, respectively. The columns of the array, from left to right, correspond to the following ranges of expected counts: less than 1, between 1 and 5, and greater than 5.

## Results for Rates

Simulation results for rates were very similar to those of proportions, and are thus not shown in detail. To convey the similarity, we show an example of the proportion bias for simulations of rates and of proportions for the comparison of approximate methods with the canonical versus the variance stabilizing transformation (Figure 30). The similarity in the results is obvious, and is theoretically expected, as the Poisson is a limiting case of the binomial distribution as the exposure increases.

Figure 30 Side by side comparison of results from simulations for proportions and rates: Comparison of proportion bias for approximate methods, canonical versus variance stabilizing transformations

Rows correspond to number of studies. Columns correspond to ranges of expected events (for rates, left side) and ranges of expected counts (for proportions, right side). Points on the dashed line have equal proportion bias for both methods. Points indicate simulation scenarios, and are coded with two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true rates or true proportions: 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1). Black color indicates scenarios with small heterogeneity, and red scenarios with large heterogeneity. Only a representative subset of scenarios is plotted. The solid black reference lines indicate 0 bias. Note the change in scale across columns, and from the left to the right panel.

The diagram shows two 3-by-2 arrays of scatter plots of scaled bias, side by side. The array on the left shows data for rates; the array on the right shows data for proportions. Each scatter plot shows the scaled bias for the variance-stabilizing transformation on the x-axis versus the scaled bias for the canonical transformation on the y-axis, for a number of points corresponding to different true rates or proportions (.001, .005, .01, .05, .1) and sample-size scenarios (small, medium, large, and mixed). The three rows of each array, from top to bottom, correspond to 5, 15, and 30 studies, respectively. The two columns of the array, from left to right, correspond to the following ranges of expected events (for rates) or expected counts (for proportions): between 1 and 5, and greater than 5.

### Overview of Results Across All Methods

Table 10 shows the proportion bias with the random effects analysis methods for selected scenarios with high heterogeneity. Table 11 and Table 12 show the corresponding proportion RMSE and coverage. We make the following general observations for scenarios with expected counts 1 or less, between 1 and 5, and 5 or more:

- For expected counts ≤1, the hybrid method has proportion bias and RMSE that are closer to zero and coverage probability closer to 95 percent compared to other methods.
- For expected counts between 1 and 5 the random effects discrete likelihood method and the approximate method with the variance stabilizing transformation have comparable performance, and better than other methods.

[For detailed descriptions and explanations refer to two sections: Pairwise Comparisons Among Approximate Methods—Random Effects Meta-Analysis and Pairwise Comparisons between Approximate and Discrete Likelihood Methods for Random Effects Meta-Analysis. Analogous points apply to simulations of rates as well.]

- For expected counts of 5 or more, the differences between methods become less evident.

Table 10 Comparison of proportion bias across random effects methods for meta-analysis of rates (selected scenarios with high heterogeneity)

Scenario | K | Rate | Exposure size | Expected count | Approximate untransformed | Approximate log | Approximate square root | Discrete (fraction converged) | Discrete (random) | Discrete (hybrid)
S1 | 5 | 0.001 | Small | 0.1 | 2.689 | 3.207 | -0.678 | 0.530 | 0.737 | -0.079
M1 | 5 | 0.001 | Medium | 0.4 | 0.722 | 1.236 | -0.561 | 0.836 | 0.080 | -0.097
S2 | 5 | 0.005 | Small | 0.7 | 0.018 | 0.573 | -0.430 | 0.972 | -0.083 | -0.109
S3 | 5 | 0.01 | Small | 1.5 | -0.276 | 0.261 | -0.289 | 1.000 | -0.103 | -0.103
M2 | 5 | 0.005 | Medium | 1.8 | -0.313 | 0.211 | -0.248 | 1.000 | -0.100 | -0.100
X1 | 5 | 0.001 | Mixed | 1.9 | 1.023 | 0.815 | -0.158 | 0.994 | 0.066 | 0.059
M3 | 5 | 0.01 | Medium | 3.6 | -0.359 | 0.073 | -0.146 | 1.000 | -0.094 | -0.094
L1 | 5 | 0.001 | Large | 5.7 | -0.337 | 0.014 | -0.130 | 1.000 | -0.100 | -0.100
S4 | 5 | 0.05 | Small | 7.3 | -0.296 | 0.012 | -0.074 | 1.000 | -0.074 | -0.074
X2 | 5 | 0.005 | Mixed | 9.4 | -0.065 | 0.161 | -0.269 | 1.000 | 0.004 | 0.004
S5 | 5 | 0.1 | Small | 14.7 | -0.243 | -0.041 | -0.060 | 1.000 | -0.084 | -0.084
M4 | 5 | 0.05 | Medium | 17.8 | -0.240 | -0.051 | -0.059 | 1.000 | -0.089 | -0.089
X3 | 5 | 0.01 | Mixed | 18.8 | -0.232 | 0.101 | -0.192 | 1.000 | -0.038 | -0.038
L2 | 5 | 0.005 | Large | 28.4 | -0.221 | -0.058 | -0.051 | 1.000 | -0.085 | -0.085
M5 | 5 | 0.1 | Medium | 35.6 | -0.220 | -0.081 | -0.064 | 1.000 | -0.101 | -0.101
L3 | 5 | 0.01 | Large | 56.8 | -0.206 | -0.076 | -0.052 | 1.000 | -0.092 | -0.092
S6 | 5 | 0.4 | Small | 58.8 | -0.207 | -0.088 | -0.057 | 1.000 | -0.099 | -0.099
X4 | 5 | 0.05 | Mixed | 93.8 | -0.275 | -0.020 | -0.078 | 1.000 | -0.075 | -0.075
M6 | 5 | 0.4 | Medium | 142.3 | -0.185 | -0.084 | -0.044 | 1.000 | -0.089 | -0.089
X5 | 5 | 0.1 | Mixed | 187.6 | -0.243 | -0.053 | -0.065 | 1.000 | -0.087 | -0.087
L4 | 5 | 0.05 | Large | 284 | -0.200 | -0.103 | -0.060 | 1.000 | -0.106 | -0.106
L5 | 5 | 0.1 | Large | 567.9 | -0.189 | -0.098 | -0.054 | 1.000 | -0.099 | -0.099
X6 | 5 | 0.4 | Mixed | 750.3 | -0.210 | -0.088 | -0.063 | 1.000 | -0.103 | -0.103
L6 | 5 | 0.4 | Large | 2271.7 | -0.166 | -0.079 | -0.033 | 1.000 | -0.076 | -0.076
S1 | 15 | 0.001 | Small | 0.1 | 3.330 | 4.002 | -0.812 | 0.849 | -0.161 | -0.288
M1 | 15 | 0.001 | Medium | 0.3 | 0.812 | 1.400 | -0.673 | 0.990 | -0.144 | -0.152
S2 | 15 | 0.005 | Small | 0.6 | 0.123 | 0.774 | -0.543 | 1.000 | -0.129 | -0.129
X1 | 15 | 0.001 | Mixed | 0.8 | 0.904 | 0.982 | -0.417 | 0.999 | -0.049 | -0.050
S3 | 15 | 0.01 | Small | 1.2 | -0.252 | 0.420 | -0.374 | 1.000 | -0.108 | -0.108
M2 | 15 | 0.005 | Medium | 1.6 | -0.343 | 0.313 | -0.303 | 1.000 | -0.103 | -0.103
M3 | 15 | 0.01 | Medium | 3.3 | -0.415 | 0.159 | -0.156 | 0.999 | -0.081 | -0.081
X2 | 15 | 0.005 | Mixed | 3.9 | -0.198 | 0.227 | -0.300 | 1.000 | -0.065 | -0.065
L1 | 15 | 0.001 | Large | 5.6 | -0.371 | 0.053 | -0.144 | 1.000 | -0.103 | -0.103
S4 | 15 | 0.05 | Small | 6.1 | -0.414 | 0.028 | -0.121 | 1.000 | -0.109 | -0.109
X3 | 15 | 0.01 | Mixed | 7.7 | -0.355 | 0.110 | -0.214 | 1.000 | -0.093 | -0.093
S5 | 15 | 0.1 | Small | 12.3 | -0.342 | -0.044 | -0.089 | 1.000 | -0.113 | -0.113
M4 | 15 | 0.05 | Medium | 16.5 | -0.307 | -0.052 | -0.072 | 1.000 | -0.105 | -0.105
L2 | 15 | 0.005 | Large | 27.9 | -0.305 | -0.070 | -0.076 | 1.000 | -0.111 | -0.111
M5 | 15 | 0.1 | Medium | 32.9 | -0.267 | -0.078 | -0.060 | 1.000 | -0.106 | -0.106
X4 | 15 | 0.05 | Mixed | 38.6 | -0.348 | -0.037 | -0.085 | 1.000 | -0.108 | -0.108
S6 | 15 | 0.4 | Small | 49.2 | -0.257 | -0.093 | -0.065 | 1.000 | -0.113 | -0.113
L3 | 15 | 0.01 | Large | 55.8 | -0.277 | -0.094 | -0.072 | 1.000 | -0.119 | -0.119
X5 | 15 | 0.1 | Mixed | 77.2 | -0.290 | -0.063 | -0.067 | 1.000 | -0.106 | -0.106
M6 | 15 | 0.4 | Medium | 131.6 | -0.232 | -0.099 | -0.051 | 1.000 | -0.106 | -0.106
L4 | 15 | 0.05 | Large | 279 | -0.231 | -0.107 | -0.059 | 1.000 | -0.113 | -0.113
X6 | 15 | 0.4 | Mixed | 309 | -0.250 | -0.099 | -0.059 | 1.000 | -0.113 | -0.113
L5 | 15 | 0.1 | Large | 558 | -0.230 | -0.112 | -0.060 | 1.000 | -0.115 | -0.115
L6 | 15 | 0.4 | Large | 2231.9 | -0.231 | -0.115 | -0.059 | 1.000 | -0.113 | -0.113
S1 | 30 | 0.001 | Small | 0.1 | 3.284 | 4.021 | -0.840 | 0.980 | -0.345 | -0.358
M1 | 30 | 0.001 | Medium | 0.3 | 0.874 | 1.489 | -0.708 | 1.000 | -0.169 | -0.169
S2 | 30 | 0.005 | Small | 0.6 | 0.109 | 0.779 | -0.559 | 1.000 | -0.134 | -0.134
X1 | 30 | 0.001 | Mixed | 0.7 | 0.820 | 1.169 | -0.441 | 1.000 | -0.095 | -0.095
S3 | 30 | 0.01 | Small | 1.2 | -0.258 | 0.459 | -0.375 | 0.999 | -0.099 | -0.099
M2 | 30 | 0.005 | Medium | 1.6 | -0.338 | 0.381 | -0.313 | 1.000 | -0.095 | -0.095
M3 | 30 | 0.01 | Medium | 3.1 | -0.436 | 0.164 | -0.185 | 0.999 | -0.101 | -0.101
X2 | 30 | 0.005 | Mixed | 3.3 | -0.208 | 0.232 | -0.304 | 1.000 | -0.096 | -0.096
L1 | 30 | 0.001 | Large | 4.6 | -0.364 | 0.100 | -0.163 | 1.000 | -0.102 | -0.102
S4 | 30 | 0.05 | Small | 6.2 | -0.421 | 0.034 | -0.115 | 1.000 | -0.105 | -0.105
X3 | 30 | 0.01 | Mixed | 6.5 | -0.349 | 0.109 | -0.207 | 1.000 | -0.103 | -0.103
S5 | 30 | 0.1 | Small | 12.4 | -0.368 | -0.035 | -0.084 | 1.000 | -0.110 | -0.110
M4 | 30 | 0.05 | Medium | 15.7 | -0.328 | -0.046 | -0.070 | 1.000 | -0.104 | -0.104
L2 | 30 | 0.005 | Large | 23.2 | -0.343 | -0.058 | -0.083 | 1.000 | -0.113 | -0.113
M5 | 30 | 0.1 | Medium | 31.5 | -0.294 | -0.091 | -0.075 | 1.000 | -0.121 | -0.121
X4 | 30 | 0.05 | Mixed | 32.5 | -0.356 | -0.032 | -0.080 | 1.000 | -0.103 | -0.103
L3 | 30 | 0.01 | Large | 46.3 | -0.303 | -0.084 | -0.070 | 1.000 | -0.115 | -0.115
S6 | 30 | 0.4 | Small | 49.8 | -0.268 | -0.091 | -0.060 | 1.000 | -0.111 | -0.111
X5 | 30 | 0.1 | Mixed | 65 | -0.324 | -0.069 | -0.074 | 1.000 | -0.113 | -0.113
M6 | 30 | 0.4 | Medium | 125.8 | -0.252 | -0.110 | -0.061 | 1.000 | -0.118 | -0.118
L4 | 30 | 0.05 | Large | 231.7 | -0.259 | -0.115 | -0.068 | 1.000 | -0.124 | -0.124
X6 | 30 | 0.4 | Mixed | 260.2 | -0.260 | -0.100 | -0.060 | 1.000 | -0.115 | -0.115
L5 | 30 | 0.1 | Large | 463.4 | -0.242 | -0.110 | -0.058 | 1.000 | -0.115 | -0.115
L6 | 30 | 0.4 | Large | 1853.4 | -0.238 | -0.114 | -0.055 | 1.000 | -0.114 | -0.114

“Discrete” stands for discrete likelihood methods. Scenarios are ordered by number of studies (K), and then by expected count. Bold horizontal lines separate scenarios by number of studies. White and grey shading separates scenarios with expected counts ≤1, between 1 and 5, and ≥5. We code scenarios using two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true rates; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1, 6=0.4).

The column “Discrete (fraction converged)” shows the proportion of simulations for which random effects methods converged successfully. Values of 1.000 mean that random effects methods converged successfully in all 1000 simulations in a scenario, and a value of e.g., 0.335 means that they converged in 335 out of 1000 simulations in a scenario. The columns “Discrete (random)” and “Discrete (hybrid)” are identical when the fraction converged is 1.000, because the random effects method was used in all simulations.

Table 11 Comparison of proportion RMSE across random effects methods for meta-analysis of rates (selected scenarios with high heterogeneity)

Scenario | K | Rate | Exposure size | Expected count | Approximate untransformed | Approximate log | Approximate square root | Discrete (fraction converged) | Discrete (random) | Discrete (hybrid)
S1 | 5 | 0.001 | Small | 0.1 | 2.716 | 3.365 | 0.862 | 0.530 | 1.180 | 1.099
M1 | 5 | 0.001 | Medium | 0.4 | 0.772 | 1.450 | 0.755 | 0.836 | 0.693 | 0.752
S2 | 5 | 0.005 | Small | 0.7 | 0.240 | 0.815 | 0.630 | 0.972 | 0.542 | 0.560
S3 | 5 | 0.01 | Small | 1.5 | 0.363 | 0.500 | 0.498 | 1.000 | 0.424 | 0.424
M2 | 5 | 0.005 | Medium | 1.8 | 0.411 | 0.458 | 0.478 | 1.000 | 0.418 | 0.418
X1 | 5 | 0.001 | Mixed | 1.9 | 1.213 | 1.005 | 0.463 | 0.994 | 0.579 | 0.582
M3 | 5 | 0.01 | Medium | 3.6 | 0.457 | 0.319 | 0.355 | 1.000 | 0.328 | 0.328
L1 | 5 | 0.001 | Large | 5.7 | 0.444 | 0.295 | 0.335 | 1.000 | 0.317 | 0.317
S4 | 5 | 0.05 | Small | 7.3 | 0.415 | 0.273 | 0.288 | 1.000 | 0.283 | 0.283
X2 | 5 | 0.005 | Mixed | 9.4 | 0.294 | 0.497 | 0.480 | 1.000 | 0.460 | 0.460
S5 | 5 | 0.1 | Small | 14.7 | 0.365 | 0.258 | 0.267 | 1.000 | 0.270 | 0.270
M4 | 5 | 0.05 | Medium | 17.8 | 0.352 | 0.238 | 0.244 | 1.000 | 0.252 | 0.252
X3 | 5 | 0.01 | Mixed | 18.8 | 0.363 | 0.394 | 0.399 | 1.000 | 0.384 | 0.384
L2 | 5 | 0.005 | Large | 28.4 | 0.334 | 0.241 | 0.243 | 1.000 | 0.250 | 0.250
M5 | 5 | 0.1 | Medium | 35.6 | 0.328 | 0.241 | 0.241 | 1.000 | 0.251 | 0.251
L3 | 5 | 0.01 | Large | 56.8 | 0.311 | 0.232 | 0.229 | 1.000 | 0.239 | 0.239
S6 | 5 | 0.4 | Small | 58.8 | 0.305 | 0.229 | 0.223 | 1.000 | 0.235 | 0.235
X4 | 5 | 0.05 | Mixed | 93.8 | 0.394 | 0.274 | 0.283 | 1.000 | 0.289 | 0.289
M6 | 5 | 0.4 | Medium | 142.3 | 0.293 | 0.236 | 0.229 | 1.000 | 0.238 | 0.238
X5 | 5 | 0.1 | Mixed | 187.6 | 0.354 | 0.250 | 0.252 | 1.000 | 0.259 | 0.259
L4 | 5 | 0.05 | Large | 284 | 0.297 | 0.235 | 0.223 | 1.000 | 0.237 | 0.237
L5 | 5 | 0.1 | Large | 567.9 | 0.294 | 0.239 | 0.228 | 1.000 | 0.240 | 0.240
X6 | 5 | 0.4 | Mixed | 750.3 | 0.306 | 0.229 | 0.224 | 1.000 | 0.240 | 0.240
L6 | 5 | 0.4 | Large | 2271.7 | 0.276 | 0.229 | 0.221 | 1.000 | 0.231 | 0.231
S1 | 15 | 0.001 | Small | 0.1 | 3.339 | 4.054 | 0.849 | 0.849 | 0.810 | 0.842
M1 | 15 | 0.001 | Medium | 0.3 | 0.827 | 1.487 | 0.722 | 0.990 | 0.520 | 0.527
S2 | 15 | 0.005 | Small | 0.6 | 0.183 | 0.877 | 0.605 | 1.000 | 0.396 | 0.396
X1 | 15 | 0.001 | Mixed | 0.8 | 0.974 | 1.065 | 0.499 | 0.999 | 0.439 | 0.440
S3 | 15 | 0.01 | Small | 1.2 | 0.282 | 0.520 | 0.451 | 1.000 | 0.292 | 0.292
M2 | 15 | 0.005 | Medium | 1.6 | 0.365 | 0.405 | 0.384 | 1.000 | 0.261 | 0.261
M3 | 15 | 0.01 | Medium | 3.3 | 0.440 | 0.248 | 0.253 | 0.999 | 0.208 | 0.208
X2 | 15 | 0.005 | Mixed | 3.9 | 0.250 | 0.392 | 0.380 | 1.000 | 0.270 | 0.270
L1 | 15 | 0.001 | Large | 5.6 | 0.405 | 0.178 | 0.228 | 1.000 | 0.200 | 0.200
S4 | 15 | 0.05 | Small | 6.1 | 0.446 | 0.162 | 0.205 | 1.000 | 0.193 | 0.193
X3 | 15 | 0.01 | Mixed | 7.7 | 0.382 | 0.253 | 0.295 | 1.000 | 0.225 | 0.225
S5 | 15 | 0.1 | Small | 12.3 | 0.384 | 0.150 | 0.172 | 1.000 | 0.185 | 0.185
M4 | 15 | 0.05 | Medium | 16.5 | 0.351 | 0.147 | 0.157 | 1.000 | 0.173 | 0.173
L2 | 15 | 0.005 | Large | 27.9 | 0.344 | 0.152 | 0.155 | 1.000 | 0.174 | 0.174
M5 | 15 | 0.1 | Medium | 32.9 | 0.309 | 0.150 | 0.144 | 1.000 | 0.167 | 0.167
X4 | 15 | 0.05 | Mixed | 38.6 | 0.388 | 0.155 | 0.169 | 1.000 | 0.180 | 0.180
S6 | 15 | 0.4 | Small | 49.2 | 0.292 | 0.156 | 0.144 | 1.000 | 0.169 | 0.169
L3 | 15 | 0.01 | Large | 55.8 | 0.315 | 0.159 | 0.147 | 1.000 | 0.174 | 0.174
X5 | 15 | 0.1 | Mixed | 77.2 | 0.333 | 0.149 | 0.151 | 1.000 | 0.171 | 0.171
M6 | 15 | 0.4 | Medium | 131.6 | 0.269 | 0.160 | 0.138 | 1.000 | 0.165 | 0.165
L4 | 15 | 0.05 | Large | 279 | 0.270 | 0.165 | 0.140 | 1.000 | 0.169 | 0.169
X6 | 15 | 0.4 | Mixed | 309 | 0.289 | 0.159 | 0.140 | 1.000 | 0.169 | 0.169
L5 | 15 | 0.1 | Large | 558 | 0.266 | 0.167 | 0.139 | 1.000 | 0.169 | 0.169
L6 | 15 | 0.4 | Large | 2231.9 | 0.265 | 0.167 | 0.136 | 1.000 | 0.168 | 0.168
S1 | 30 | 0.001 | Small | 0.1 | 3.288 | 4.051 | 0.853 | 0.980 | 0.704 | 0.711
M1 | 30 | 0.001 | Medium | 0.3 | 0.881 | 1.534 | 0.728 | 1.000 | 0.418 | 0.418
S2 | 30 | 0.005 | Small | 0.6 | 0.144 | 0.835 | 0.588 | 1.000 | 0.300 | 0.300
X1 | 30 | 0.001 | Mixed | 0.7 | 0.873 | 1.206 | 0.490 | 1.000 | 0.332 | 0.332
S3 | 30 | 0.01 | Small | 1.2 | 0.273 | 0.515 | 0.416 | 0.999 | 0.222 | 0.222
M2 | 30 | 0.005 | Medium | 1.6 | 0.349 | 0.431 | 0.358 | 1.000 | 0.206 | 0.206
M3 | 30 | 0.01 | Medium | 3.1 | 0.448 | 0.214 | 0.235 | 0.999 | 0.173 | 0.173
X2 | 30 | 0.005 | Mixed | 3.3 | 0.235 | 0.314 | 0.344 | 1.000 | 0.200 | 0.200
L1 | 30 | 0.001 | Large | 4.6 | 0.385 | 0.163 | 0.210 | 1.000 | 0.166 | 0.166
S4 | 30 | 0.05 | Small | 6.2 | 0.438 | 0.122 | 0.166 | 1.000 | 0.157 | 0.157
X3 | 30 | 0.01 | Mixed | 6.5 | 0.366 | 0.192 | 0.253 | 1.000 | 0.178 | 0.178
S5 | 30 | 0.1 | Small | 12.4 | 0.391 | 0.104 | 0.131 | 1.000 | 0.148 | 0.148
M4 | 30 | 0.05 | Medium | 15.7 | 0.354 | 0.112 | 0.126 | 1.000 | 0.146 | 0.146
L2 | 30 | 0.005 | Large | 23.2 | 0.363 | 0.113 | 0.129 | 1.000 | 0.148 | 0.148
M5 | 30 | 0.1 | Medium | 31.5 | 0.316 | 0.128 | 0.119 | 1.000 | 0.152 | 0.152
X4 | 30 | 0.05 | Mixed | 32.5 | 0.376 | 0.109 | 0.130 | 1.000 | 0.143 | 0.143
L3 | 30 | 0.01 | Large | 46.3 | 0.325 | 0.124 | 0.117 | 1.000 | 0.148 | 0.148
S6 | 30 | 0.4 | Small | 49.8 | 0.289 | 0.125 | 0.106 | 1.000 | 0.141 | 0.141
X5 | 30 | 0.1 | Mixed | 65 | 0.346 | 0.120 | 0.123 | 1.000 | 0.149 | 0.149
M6 | 30 | 0.4 | Medium | 125.8 | 0.270 | 0.140 | 0.107 | 1.000 | 0.146 | 0.146
L4 | 30 | 0.05 | Large | 231.7 | 0.277 | 0.146 | 0.115 | 1.000 | 0.153 | 0.153
X6 | 30 | 0.4 | Mixed | 260.2 | 0.280 | 0.131 | 0.104 | 1.000 | 0.143 | 0.143
L5 | 30 | 0.1 | Large | 463.4 | 0.260 | 0.139 | 0.105 | 1.000 | 0.143 | 0.143
L6 | 30 | 0.4 | Large | 1853.4 | 0.256 | 0.142 | 0.102 | 1.000 | 0.143 | 0.143

“Discrete” stands for discrete likelihood methods. Scenarios are ordered by number of studies (K), and then by expected count. Bold horizontal lines separate scenarios by number of studies. White and grey shading separates scenarios with expected counts ≤1, between 1 and 5, and ≥5. We code scenarios using two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true rates; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1, 6=0.4).

The column “Discrete (fraction converged)” shows the proportion of simulations for which random effects methods converged successfully. Values of 1.000 mean that random effects methods converged successfully in all 1000 simulations in a scenario, and a value of e.g., 0.335 means that they converged in 335 out of 1000 simulations in a scenario. The columns “Discrete (random)” and “Discrete (hybrid)” are identical when the fraction converged is 1.000, because the random effects method was used in all simulations.

Table 12 Comparison of coverage across random effects methods for meta-analysis of rates (selected scenarios with high heterogeneity)

Scenario | K | Rate | Exposure size | Expected count | Approximate untransformed | Approximate log | Approximate square root | Discrete (fraction converged) | Discrete (random) | Discrete (hybrid)
S1 | 5 | 0.001 | Small | 0.1 | 1.000 | 0.000 | 0.999 | 0.530 | 0.947 | 0.972
M1 | 5 | 0.001 | Medium | 0.4 | 1.000 | 0.737 | 0.836 | 0.836 | 0.963 | 0.969
S2 | 5 | 0.005 | Small | 0.7 | 1.000 | 0.849 | 0.824 | 0.972 | 0.971 | 0.972
S3 | 5 | 0.01 | Small | 1.5 | 1.000 | 0.912 | 0.891 | 1.000 | 0.964 | 0.964
M2 | 5 | 0.005 | Medium | 1.8 | 1.000 | 0.907 | 0.894 | 1.000 | 0.946 | 0.946
X1 | 5 | 0.001 | Mixed | 1.9 | 1.000 | 0.737 | 0.796 | 0.994 | 0.788 | 0.783
M3 | 5 | 0.01 | Medium | 3.6 | 1.000 | 0.929 | 0.899 | 1.000 | 0.942 | 0.942
L1 | 5 | 0.001 | Large | 5.7 | 1.000 | 0.904 | 0.865 | 1.000 | 0.879 | 0.879
S4 | 5 | 0.05 | small | 7.3 | 1.000 | 0.897 | 0.868 | 1.000 | 0.876 | 0.876
X2 | 5 | 0.005 | mixed | 9.4 | 1.000 | 0.643 | 0.789 | 1.000 | 0.557 | 0.557
S5 | 5 | 0.1 | small | 14.7 | 1.000 | 0.864 | 0.842 | 1.000 | 0.826 | 0.826
M4 | 5 | 0.05 | medium | 17.8 | 1.000 | 0.886 | 0.867 | 1.000 | 0.853 | 0.853
X3 | 5 | 0.01 | mixed | 18.8 | 1.000 | 0.625 | 0.789 | 1.000 | 0.545 | 0.545
L2 | 5 | 0.005 | large | 28.4 | 1.000 | 0.877 | 0.870 | 1.000 | 0.842 | 0.842
M5 | 5 | 0.1 | medium | 35.6 | 0.998 | 0.851 | 0.840 | 1.000 | 0.825 | 0.825
L3 | 5 | 0.01 | large | 56.8 | 1.000 | 0.856 | 0.869 | 1.000 | 0.845 | 0.845
S6 | 5 | 0.4 | small | 58.8 | 0.995 | 0.869 | 0.875 | 1.000 | 0.846 | 0.846
X4 | 5 | 0.05 | mixed | 93.8 | 1.000 | 0.817 | 0.809 | 1.000 | 0.718 | 0.718
M6 | 5 | 0.4 | medium | 142.3 | 0.998 | 0.828 | 0.849 | 1.000 | 0.813 | 0.813
X5 | 5 | 0.1 | mixed | 187.6 | 0.999 | 0.827 | 0.815 | 1.000 | 0.776 | 0.776
L4 | 5 | 0.05 | large | 284 | 1.000 | 0.827 | 0.851 | 1.000 | 0.809 | 0.809
L5 | 5 | 0.1 | large | 567.9 | 1.000 | 0.810 | 0.828 | 1.000 | 0.789 | 0.789
X6 | 5 | 0.4 | mixed | 750.3 | 0.993 | 0.823 | 0.820 | 1.000 | 0.802 | 0.802
L6 | 5 | 0.4 | large | 2271.7 | 0.999 | 0.831 | 0.851 | 1.000 | 0.784 | 0.784
S1 | 15 | 0.001 | small | 0.1 | 1.000 | 0.000 | 0.542 | 0.849 | 0.967 | 0.972
M1 | 15 | 0.001 | medium | 0.3 | 1.000 | 0.168 | 0.444 | 0.990 | 0.980 | 0.970
S2 | 15 | 0.005 | small | 0.6 | 1.000 | 0.503 | 0.545 | 1.000 | 0.980 | 0.980
X1 | 15 | 0.001 | mixed | 0.8 | 1.000 | 0.232 | 0.681 | 0.999 | 0.912 | 0.911
S3 | 15 | 0.01 | small | 1.2 | 1.000 | 0.624 | 0.710 | 1.000 | 0.965 | 0.965
M2 | 15 | 0.005 | medium | 1.6 | 1.000 | 0.713 | 0.774 | 1.000 | 0.949 | 0.949
M3 | 15 | 0.01 | medium | 3.3 | 1.000 | 0.833 | 0.875 | 0.999 | 0.930 | 0.930
X2 | 15 | 0.005 | mixed | 3.9 | 1.000 | 0.661 | 0.730 | 1.000 | 0.837 | 0.837
L1 | 15 | 0.001 | large | 5.6 | 1.000 | 0.928 | 0.856 | 1.000 | 0.897 | 0.897
S4 | 15 | 0.05 | small | 6.1 | 1.000 | 0.921 | 0.869 | 1.000 | 0.890 | 0.890
X3 | 15 | 0.01 | mixed | 7.7 | 1.000 | 0.773 | 0.780 | 1.000 | 0.851 | 0.851
S5 | 15 | 0.1 | small | 12.3 | 0.999 | 0.917 | 0.874 | 1.000 | 0.854 | 0.854
M4 | 15 | 0.05 | medium | 16.5 | 1.000 | 0.901 | 0.880 | 1.000 | 0.842 | 0.842
L2 | 15 | 0.005 | large | 27.9 | 1.000 | 0.887 | 0.893 | 1.000 | 0.865 | 0.865
M5 | 15 | 0.1 | medium | 32.9 | 0.996 | 0.882 | 0.897 | 1.000 | 0.856 | 0.856
X4 | 15 | 0.05 | mixed | 38.6 | 1.000 | 0.906 | 0.865 | 1.000 | 0.859 | 0.859
S6 | 15 | 0.4 | small | 49.2 | 0.978 | 0.825 | 0.870 | 1.000 | 0.821 | 0.821
L3 | 15 | 0.01 | large | 55.8 | 1.000 | 0.836 | 0.868 | 1.000 | 0.822 | 0.822
X5 | 15 | 0.1 | mixed | 77.2 | 0.997 | 0.884 | 0.863 | 1.000 | 0.847 | 0.847
M6 | 15 | 0.4 | medium | 131.6 | 0.990 | 0.816 | 0.895 | 1.000 | 0.835 | 0.835
L4 | 15 | 0.05 | large | 279 | 1.000 | 0.787 | 0.885 | 1.000 | 0.823 | 0.823
X6 | 15 | 0.4 | mixed | 309 | 0.979 | 0.804 | 0.874 | 1.000 | 0.827 | 0.827
L5 | 15 | 0.1 | large | 558 | 1.000 | 0.783 | 0.877 | 1.000 | 0.814 | 0.814
L6 | 15 | 0.4 | large | 2231.9 | 0.993 | 0.778 | 0.893 | 1.000 | 0.810 | 0.810
S1 | 30 | 0.001 | small | 0.1 | 1.000 | 0.000 | 0.223 | 0.980 | 0.978 | 0.958
M1 | 30 | 0.001 | medium | 0.3 | 1.000 | 0.000 | 0.192 | 1.000 | 0.980 | 0.980
S2 | 30 | 0.005 | small | 0.6 | 1.000 | 0.174 | 0.306 | 1.000 | 0.970 | 0.970
X1 | 30 | 0.001 | mixed | 0.7 | 1.000 | 0.000 | 0.470 | 1.000 | 0.931 | 0.931
S3 | 30 | 0.01 | small | 1.2 | 1.000 | 0.362 | 0.508 | 0.999 | 0.963 | 0.963
M2 | 30 | 0.005 | medium | 1.6 | 1.000 | 0.398 | 0.620 | 1.000 | 0.934 | 0.934
M3 | 30 | 0.01 | medium | 3.1 | 1.000 | 0.754 | 0.747 | 0.999 | 0.887 | 0.887
X2 | 30 | 0.005 | mixed | 3.3 | 1.000 | 0.598 | 0.569 | 1.000 | 0.886 | 0.886
L1 | 30 | 0.001 | large | 4.6 | 1.000 | 0.829 | 0.764 | 1.000 | 0.884 | 0.884
S4 | 30 | 0.05 | small | 6.2 | 1.000 | 0.926 | 0.815 | 1.000 | 0.848 | 0.848
X3 | 30 | 0.01 | mixed | 6.5 | 1.000 | 0.796 | 0.676 | 1.000 | 0.866 | 0.866
S5 | 30 | 0.1 | small | 12.4 | 0.989 | 0.935 | 0.848 | 1.000 | 0.803 | 0.803
M4 | 30 | 0.05 | medium | 15.7 | 1.000 | 0.884 | 0.862 | 1.000 | 0.784 | 0.784
L2 | 30 | 0.005 | large | 23.2 | 1.000 | 0.886 | 0.838 | 1.000 | 0.788 | 0.788
M5 | 30 | 0.1 | medium | 31.5 | 0.994 | 0.809 | 0.859 | 1.000 | 0.739 | 0.739
X4 | 30 | 0.05 | mixed | 32.5 | 1.000 | 0.927 | 0.860 | 1.000 | 0.834 | 0.834
L3 | 30 | 0.01 | large | 46.3 | 1.000 | 0.836 | 0.865 | 1.000 | 0.762 | 0.762
S6 | 30 | 0.4 | small | 49.8 | 0.935 | 0.796 | 0.883 | 1.000 | 0.770 | 0.770
X5 | 30 | 0.1 | mixed | 65 | 0.997 | 0.853 | 0.840 | 1.000 | 0.760 | 0.760
M6 | 30 | 0.4 | medium | 125.8 | 0.961 | 0.710 | 0.877 | 1.000 | 0.728 | 0.728
L4 | 30 | 0.05 | large | 231.7 | 1.000 | 0.677 | 0.838 | 1.000 | 0.704 | 0.704
X6 | 30 | 0.4 | mixed | 260.2 | 0.946 | 0.737 | 0.870 | 1.000 | 0.749 | 0.749
L5 | 30 | 0.1 | large | 463.4 | 1.000 | 0.692 | 0.873 | 1.000 | 0.741 | 0.741
L6 | 30 | 0.4 | large | 1853.4 | 0.980 | 0.666 | 0.886 | 1.000 | 0.730 | 0.730

“Discrete” stands for discrete likelihood methods. Scenarios are ordered by number of studies (K), and then by expected count. Bold horizontal lines separate scenarios by number of studies. White and grey shading separates scenarios with expected counts ≤1, between 1 and 5, and ≥5. We code scenarios using two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true rates; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1, 6=0.4).

The column “Discrete (fraction converged)” shows the proportion of simulations for which random effects methods converged successfully. Values of 1.000 mean that random effects methods converged successfully in all 1000 simulations in a scenario, and a value of e.g., 0.335 means that they converged in 335 out of 1000 simulations in a scenario. The columns “Discrete (random)” and “Discrete (hybrid)” are identical when the fraction converged is 1.000, because the random effects method was used in all simulations.

For numerical reasons, the random effects discrete likelihood method does not always converge. The following general comments can be made:

- For very small expected counts (<0.5) and for K=5 or K=15 the random effects discrete likelihood method reached convergence for fewer than 85 percent of the simulations (see column “Discrete (fraction converged)”). For expected counts above 1 or for K=30, the method converges practically for all simulations.
- For expected counts above 1 the random effect discrete likelihood method converged (almost) always, and thus the performance of the hybrid strategy is identical to that with random effects.

The random effects discrete likelihood method will not converge when all studies in a meta-analysis have 0 events. This is more common in simulation scenarios with very low expected counts and when the number of studies is small.

We can make the following general comments on the preferred methods (hybrid strategy-discrete likelihood and variance-stabilizing transformation-approximate likelihood):

- For expected counts larger than 10, the hybrid strategy for meta-analysis using the discrete likelihood has larger absolute bias than the approximate method using the variance stabilizing transformation, and the reverse for smaller counts.

[The explanations are analogous to those in two sections (Pairwise Comparisons Among Approximate Methods—Random Effects Meta-Analysis and Pairwise Comparisons Between Approximate and Discrete Likelihood Methods for Random Effects Meta-Analysis) for proportions; briefly, the discrete likelihood methods appear to have a constant relative bias of approximately -10 percent when heterogeneity is large, and when the expected number of counts is >5]

- For very large expected counts (for example when the true rate is 0.4) all compared methods converge in proportion bias and proportion RMSE.

This is congruent with what we expect theoretically: the normal approximation to the Poisson improves with increasing expected counts.

- The hybrid strategy using the discrete likelihood has better coverage probabilities than the other methods for the widest range of scenarios.

Finally, in sensitivity analyses that used numerical integration instead of a simple transformation to obtain the meta-analysis point estimates in the rate scale (see Methods section, paragraph on Approximate Methods), results were very comparable with those reported in Table 11 and Table 12 (not shown).

## Practical Recommendations for Meta-Analysis of Proportions or Rates

The following are practical recommendations for meta-analysts, and probably apply generally. For most meta-analyses we would think that a random effects analysis will be adopted, because clinical and methodological diversity are more often present than not.

- Recommendation 1: Use meta-analysis methods that model within study data using the binomial likelihood (for proportions) or the Poisson likelihood (for rates). If the number of events is 0 for the vast majority of studies, the random effects methods may not converge. It is reasonable to use a hybrid strategy where if the random effects analysis fails to converge, one performs a meta-analysis with the fixed effects discrete likelihood method.
- Recommendation 2: If recommendation 1 cannot be followed, i use meta-analysis models that rely on a variance stabilizing transformation (arcsine for proportions and square root for rates along with the normal approximation to the binomial (for proportions) or the Poisson (for rates).
  i For example, if someone does not have access to software that can perform the analyses suggested in Recommendation 1.

Recommendations 1 and 2 both favor methods that do not suffer from the correlation between the estimate of the proportion and its variance (or the estimate of the rate and its variance), which is a problem with approximate methods on untransformed or canonically transformed proportions (rates). Further, using methods other than those in recommendations 1 and 2 may necessitate continuity corrections in applications with rare events. Continuity corrections can yield very biased summary proportions or rates, and thus should be avoided. Therefore, using methods other than the ones above recommended above can affect the meta-analysis summary results and conclusions.

If the estimated proportions and sample sizes in all studies are such that the expected number of events and the expected number of no events are relatively large (e.g., at least 5) the examined methods converge. Thus the choice of method is arguably less important. Similarly for rates, methods converge when the expected numbers of events are relatively large for all studies (e.g., more than 5).