# References

1 Kent DM, Trikalinos TA. Are “treatment” bare metal stents superior to “control” bare metal stents? A meta-analytic approach. Am Heart J. Apr. 2008;155(4):624-9. [pmid: 18371468].
2 Alsheikh-Ali AA, Trikalinos TA, Kent DM, Karas RH. Statins, low-density lipoprotein cholesterol, and risk of cancer. J Am Coll Cardiol. Sep. 30. 2008;52(14):1141-7. [pmid: 18804740].
3 Chappell FM, Raab GM, Wardlaw JM. When are summary ROC curves appropriate for diagnostic meta-analyses?. Stat med. Sep. 20. 2009;28(21):2653-68. [pmid: 19591118].
4 Trikalinos TA, Balion CM, Coleman CI, et al. Chapter 8: Meta-analysis of test performance when there is a “gold standard”. J Gen Intern Med. Jun. Suppl 1. 2012;27:S56-66. [pmid: 22648676].
5 Chang BH, Waternaux C, Lipsitz S. Meta-analysis of binary data: which within study variance estimate to use?. Stat med. Jul. 15. 2001;20(13):1947-56. [pmid: 11427951].
6 Hamza TH, van Houwelingen HC, Stijnen T. The binomial distribution of meta-analysis was preferred to model within-study variability. J Clin Epidemiol. Jan. 2008;61(1):41-51. [pmid: 18083461].
7 Platt RW, Leroux BG, Breslow N. Generalized linear mixed models for meta-analysis. Stat med. Mar. 30. 1999;18(6):643-54. [pmid: 10204195].
8 Dahabreh IJ, Chung M, Kitsios GD, et al. Comprehensive Overview of Methods and Reporting of Meta-Analyses of Test Accuracy. AHRQ Methods for Effective Health Care. AHRQ Publication No.: 12-EHC044-EF. Rockville, MD. Agency for Healthcare Research and Quality (US). 2012. Mar.
9 Kulinskaya E, Morgenthaler S, Staudte RG. Meta-analysis: a guide to calibrating and combining statistical evidence. Sussex, England. Wiley. 2008.
10 Skrondal A, Rabe-Hesketh S. Generalized latent variable modeling: Multilevel, longitudinal, and structural equation models. Boca Raton, FL. Chapman & Hall/CRC. 2004.
11 Stata Corp. Stata longitudinal-data/panel-data reference manual. Release 11. College Station, TX. Stata Press. 2009.
12 Rabe-Hesketh S, Skrondal A. Multilevel and longitudinal modeling using Stata. 2 ed. College Station, TX. Stata Press. 2008.
13 Wallace BC, Schmid CH, Lau J, Trikalinos TA. Meta-Analyst: software for meta-analysis of binary, continuous and diagnostic data. BMC medical research methodology. 2009;9:80. [pmid: 19961608].
14 Wallace BC, Dahabreh IJ, Trikalinos TA, et al. Closing the Gap Between Methodologists and End-Users: R as a Computational Back-end. J Stat Software. 2013;49:1-15.
15 Brown LD, Cai TT, DasGupta A. Confidence intervals for a binomial proportion and asymptotic expansions. Ann Stat. Feb. 2002;30(1):160-201.
16 Brown LD, Cai TT, DasGupta A, et al. Interval estimation for a binomial proportion—Comment—Rejoinder. Stat Sci. May. 2001;16(2):101-33.
17 Agresti A, Coull BA. Approximate is better than “exact” for interval estimation of binomial proportions. Am Stat. May. 1998;52(2):119-26.
18 Agresti A, Caffo B. Simple and effective confidence intervals for proportions and differences of proportions result from adding two successes and two failures. Am Stat. Nov. 2000;54(4):280-8.
19 Stijnen T, Hamza TH, Ozdemir P. Random effects meta-analysis of event outcome in the framework of the generalized linear mixed model with applications in sparse data. Stat med. Dec. 20. 2010;29(29):3046-67. [pmid: 20827667].
20 Hedges LV, Olkin I. Statistical methods for meta-analysis. London, UK. Academic Press. 1985.
21 DerSimonian R, Laird N. Meta-analysis in clinical trials. Controlled clinical trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
22 Bishop CM. Pattern recognition and machine learning. Singapore. Springer. 2006.
23 Bax L, Yu LM, Ikeda N, Moons KG. A systematic comparison of software dedicated to meta-analysis of causal studies. BMC medical research methodology. 2007;7:40. [pmid: 17845719].