# Methods

## Overview

Figure 1 outlines our simulation approach. Briefly, we generated 792 distinct scenarios for meta-analyses of proportions, and 792 scenarios for meta-analyses of incidence rates. These are formed by all possible combinations of choices for the parameters of our generative model.

Figure 1 Outline of the simulation analysis

The schematic diagram shows the parameters for the various simulation scenarios, including the distribution from which the proportions (or rates) are drawn, the mean (pi or lambda) of the distribution, the variance (tau squared) of the distribution (the heterogeneity), the number of studies (K) per meta-analysis, and the study sample sizes (N).

For each scenario we generated 1,000 random meta-analyses, and analyzed all of them with the methods of interest using both fixed and random effects approaches. We quantified the performance of each method by calculating its bias, mean square error and coverage probability. Table 1 defines these performance metrics.

Table 1 Description of performance metrics for the estimated summary proportions and rates

Metric | Formula | Description | Comment
Bias | ∑_i = 1_^1000^ (( π_j_ − π^_ij_ ))/(1000) ∑_i = 1_^1000^ (( λ_j_ − λ^_ij_ ))/(1000) | The average difference between the true (simulated) proportion and its estimate across the 1000 simulation replicates in scenario j. Similar definition for rates. | - Desirable to have bias near zero.
Proportion Bias | ∑_i = 1_^1000^ (( π_j_ − π^_ij_ ))/(1000 π_j_) ∑_i = 1_^1000^ (( λ_j_ − λ^_ij_ ))/(1000 λ_j_) | Bias scaled by π_j_ or λ_j_ to make it a proportion of the average effect | - To compare across scenarios with different true proportions and rates
Square root of the mean squared error (RMSE) | ∑_i = 1_^1000^ (( π_j_ − π^_ij_ )^2^)/(1000) ∑_i = 1_^1000^ (( λ_j_ − λ^_ij_ )^2^)/(1000) | The (square root of the) average squared difference between the true (simulated) proportion and its estimate across the 1000 simulation replicates in scenario j. Similar definition for rates | - Desirable to have RMSE near zero.; - To compare across scenarios with different true proportions π_j_, scale RMSE by π_j_ (Similarly for rates λ_j_); - RMSE can be high even if bias is 0, because positive and negative deviations of the estimates from the true mean do not cancel out.; - Mean squared error is the sum of the variance of the estimates plus the square of their bias.
Proportion RMSE | ∑_i = 1_^1000^ (( π_j_ − π^_ij_ )^2^)/(1000 π_j_) ∑_i = 1_^1000^ (( λ_j_ − λ^_ij_ )^2^)/(1000 λ_j_) | Bias scaled by π_j_ or λ_j_ to make it a proportion of the average effect | - To compare across scenarios with different true proportions and rates.
Coverage probability | ∑_i = 1_^1000^ I ( π_j_ ∈ ( 95 % CI of π^_j_ )_i_ ) / 1000 ∑_i = 1_^1000^ I ( λ_j_ ∈ ( 95 % CI of λ^_j_ )_i_ ) / 1000 | The proportion of times the two-sided 95% confidence interval (Wald-type based on normal distribution) of the estimated summary proportion contains the true proportion (or rate). | - Desirable to have coverage near 95%.; ○ Coverage higher than 95% means that π̂ or λ̂ is an inefficient estimator; ○ Coverage less than 95% indicates an inaccurate estimator; Unlike bias and RMSE, coverage does not need scaling to compare across scenarios.

Simulation scenario is denoted by j; the specific random simulation under scenario j is denoted by i. π_j_ is the true proportion in scenario j, and its estimate by a meta-analysis method in simulation i for scenario j is denoted by π_i j_^ . Similarly, λ_j_ is the true rate and its estimate is λ_ij_^ , in simulation i.

In the following sections we describe the simulation parameters, the meta-analytic methods compared and our choices for conveying the results of the simulations.

## Description of Simulations

### Simulation Parameters

Table 2 shows the simulation parameters for proportions. Each simulation scenario represents combinations of the options in the table. The first row has options for the true distribution of the summary proportions across studies. We explicitly avoided choosing a logit-normal distribution for proportions or a log-normal distribution for rates, so as not to bias the results of the simulation study in favor of meta-analytic methods that assume these distributions for the random effects. Further, the examined values cover a wide range of realistic scenarios. For example, the true value of the proportion is varied from near the extreme of zero (π = 0.001) to π = 0.50. Because all meta-analysis methods examined for proportions are symmetric around π = 0.50, it is not necessary to span the range of values between 0.50 and 1 in the simulations. For example, results and conclusions for π = 0.001 and 1 − π = 0.999 are “mirror images” around π = 0.50. Regarding heterogeneity, τ^2^, we assumed that it could take three levels: zero, small, and large. Zero heterogeneity corresponds to fixed-effects realities, and is probably not the norm in real-life applications. Positive heterogeneity values are more likely to be encountered in reallife applications.

Table 2 Simulation parameters for proportions

# | Parameter | Values
1 | Distribution of summary proportions across studies | [underlined: Beta], uniform^f^ (see Appendix for details)
2 | True summary proportion, π | [underlined: 0.001], 0.002, [underlined: 0.005], [underlined: 0.01], 0.02, [underlined: 0.05], [underlined: 0.10], 0.20, 0.30, [underlined: 0.40], [underlined: 0.50]
3 | Number of studies, K | [underlined: 5], [underlined: 15], [underlined: 30]
4 | Sample sizes, N^*^ | Vectors of sample [underlined: sizes] for the following choices: All sample sizes [underlined: small] (5-50 patients per study) All sample sizes [underlined: medium] (51-200 patients per study) All sample sizes [underlined: large] (201-1000 patients per study) [underlined: Mixed] sample sizes – approximately 50% small, 40% medium, and 10% large.
5 | Heterogeneity, τ^2^ | Three levels: zero, [underlined: small], and [underlined: large]. To determine τ, the square root of the heterogeneity variance, true summary proportions were multiplied by 0.10 or 0.50 for small or large heterogeneity, respectively.
6 | Correction factor, c^†^ | 0, 0.001, 0.01, 0.10, [underlined: 0.5], 1, 2

For parsimony, in the Results section we present in detail scenarios corresponding to the [underlined: underlined] choices. The index j for the scenario has been dropped.

* The exact values for sample sizes used in the simulations are given in the Appendix.

† Some meta-analysis methods require the use of correction factors. See Continuity Correction Factors for details. The correction factor is an analytic choice and not a simulation parameter; however it is listed here for parsimony.

f Strictly speaking, a uniform is a special case of the beta distribution, i.e., Beta(1, 1). The Appendix provides details on the parameters of the modal beta distributions used in the simulations.

Table 3 shows the respective simulation parameters for rates. In contrast to proportions, the vast majority of incidence rates in applications take very small values. In the simulations, the true rate λ was varied from 1 to 50 events per 1000 person-years.

Table 3 Simulation parameters for rates

# | Parameter | Description or Values
1 | Distribution of summary rates across studies | [underlined: Gamma], uniform (see Appendix for details)
2 | True summary rate, λ | [underlined: 0.001], 0.002, [underlined: 0.005], [underlined: 0.01], 0.02, [underlined: 0.05], [underlined: 0.10], 0.20, 0.30, 0.40, 0.50
3 | Number of studies, K | [underlined: 5], [underlined: 15], [underlined: 30]
4 | Exposures, E^*^ | Vectors of exposures for the following choices:; a. All sample sizes [underlined: small] (50-200 person-years per study); b. All sample sizes [underlined: medium] (201-500 person-years per study); c. All sample sizes [underlined: large] (501-10000 person-years per study); d. [underlined: Mixed] sample sizes – approximately 50% small, 40% medium, and 10 % large.
5 | Heterogeneity, τ^2^ | Three levels: zero, [underlined: small], and [underlined: large]. To determine τ the square root of the heterogeneity, true summary rates were multiplied by 0.10 or 0.50 for small or large heterogeneity, respectively.
6 | Correction factor, c † | 0, 0.001, 0.01, 0.10, [underlined: 0.5], 1, 2

For parsimony, in the Results section we present in detail scenarios corresponding the [underlined: underlined] choices. The index j for the scenario has been dropped.

* The vectors of the exact values for sample sizes used in the simulations are given in the Appendix.

† Some meta-analysis methods require the use of correction factors. See text for details. See Continuity Correction Factors for details. The correction factor is an analytic choice and not a simulation parameter; however it is listed here for parsimony.

### Generation of Random Data

For each scenario we generated 1000 random meta-analyses of proportions or rates. The following pseudo-algorithm describes the process for scenario j (all subscripts for the scenario have been dropped for notational simplicity). The pseudo-algorithm in Table 4 refers to parameters in Table 2 or Table 3, as applicable. We assumed a binomial sampling distribution for proportions and a Poisson sampling distribution for rates so that the model fitting algorithms based on these assumptions are exact.

Table 4 Pseudo-algorithm for generating random data

Step | Description | Simulation Table Row # | Comment
| For a given simulation scenario j:^*^
1 | Choose the form of the distribution for true proportion (or true rate) in each study in the simulated meta-analyses | 1
2 | Choose the average true proportion π (or average true rate λ) | 2
3 | Choose the number of studies, K | 3
4 | Choose the sample sizes for the K studies to be a vector of sample sizes N = (n_1_,…,n_K_) for proportions [or exposures E = (e_1_,…,e_K_) for rates] | 4 | N and E were drawn once randomly for each K and exposure level , and were then kept fixed for all simulations.
5 | Choose τ^2^ | 5
6 | Using the distribution specified in steps 1, 2 and 5, generate 1000 random vectors of true probabilities (or true rates) for the K studies: Π_i_ = (π_i1_,…,π_iK_) for proportions, or Λ_i_ = (λ_i1_,…,λ_iK_) for rates, where i indexes a random vector, i = 1,…,1000. | 1, 2, 5 | If τ^2^=0 in Step 5, all π_ik_ = π for proportions, the value chosen in Step 2. Similarly, all λ_ik_ = λ for rates. Formulas for calculating the parameters of beta and uniform distributions for proportions (or gamma and uniform distributions for rates) with a given mean and standard deviation are given in the Appendix.
7 | Generate 1000 vectors of random data, corresponding to the numbers of events in each study: For proportions the random vector of events, X_i_ = (x_i1_,…,x_iK_), is drawn from binomial distributions with probabilities Π_i_ and sample sizes N. For rates, the random vector of counts, Y_i_ = (y_i1_,…,y_iK_), is drawn from Poisson distributions with true rates Λ_i_ and exposures E.

* For ease of read, the index j for the simulation scenario has been dropped from the notation in the table. The symbol i indexes a random meta-analysis, and k indexes a study in a meta-analysis.

We verified the fidelity of the simulations by comparing the mean and variance of the empirical distributions of the true values of the simulated proportions or rates for all scenarios versus the respective simulation parameters.

### Meta-Analysis Methods

The underlying outcomes are either binary events (for which the proportion is the mean event rate) or counts of events (for which the incidence rate is the mean event rate per unit of exposure). Assuming these events are independent with nonvarying rates, the binary outcomes follow binomial distributions and the count outcomes follow Poisson distributions. Methods that use these distributions are called “discrete likelihood” methods. When sample sizes are large enough,^g^ however, the logit transformation of proportions and the logarithmic transformation of rates approximate normal distributions, and methods for normal distributions may be used. The latter are called “approximate” methods.

g More accurately, when the expected numbers in all cells (for proportions) or the expected number of counts (for rates) is relatively large, e.g., >5.

We performed both fixed and random effects meta-analyses for both approximate and discrete likelihood methods. For approximate methods, fixed effects meta-analysis used inverse variance weights,20 and random effects meta-analysis used the moment-based (non-iterative) estimator for between study variance as per DerSimonian and Laird.21

For discrete likelihood methods, the meta-analysis was performed in the generalized linear models framework for fixed effects, and the GLMM framework for random effects. For GLMMs we used 12 integration points after examining the robustness of results obtained with 1, 4, 8, 12, 16, and 20 integration points in two example meta-analyses (one with 5 and one with 30 studies of medium sample size, a true proportion or rate of 0.20 and large heterogeneity).

#### Approximate Methods

Table 5 shows formulas for the three approximate methods used in the simulation: untransformed rates and proportions, canonical transformations (logit and log) and variance stabilizing (arcsine and square root). From the formulas in the table, zero events (x_j,ik_ = 0) in, study k of simulation i in scenario j will result in an estimated variance of zero for untransformed proportions and rates, and an undefined estimate and variance for proportions and rates with the canonical transformation. In such pathological cases, inverse variance weights are undefined and continuity correction factors are typically used to make calculations possible, as explained below. Note that because of symmetry, the correction is also needed when x_j,ik_ = n_j,k_ as well (but only for proportions). We opted to examine the behavior of approximate methods using the continuity correction factors, because this is a strategy that many meta-analyses follow in practice.

Table 5 Formulas for the approximate methods for meta-analysis of proportions and rates in a study

| Proportions Estimated Mean | Proportions Estimated Variance | Rates Estimated Mean | Rates Estimated Variance
Untransformed proportions or rates | p_j , i k_ = (x_j , i k_)/(n_j , k_) [cc optional] | (p_j , i k_ ( 1 − p_j , i k_ ))/(n_j , k_) [cc needed] | l_j , i k_ = (y_j , i k_)/(e_j , k_) [cc optional] | l_j,ik_ [cc needed]
Canonical transformations^*^ | log (p_j , i k_)/(1 − p_j , i k_) [cc needed] | (1)/(x_j , i k_) + (1)/(n_j , k_ − x_j , i k_) [cc needed] | log(l_j,ik_) [cc needed] | (1)/(y_j , i k_) [cc needed]
Variance stabilizing transformations^†^ | arcsin ( sqrt(p_j , i k_) ) [no cc] | (1)/(4 n_j , k_) [no cc] | sqrt(l_j , i k_) [no cc] | (1)/(4 e_j , k_) [no cc]

cc: continuity correction.

In the Table j indexes the scenario. p_i k_ = π_i k_^ and l_i k_ = λ_i k_^ are estimates of the true proportions and rates, respectively, in study k of simulation i. The notation is the same as in Table 4 and in the text.

* Canonical transformations: the logit transformation for proportions and the logarithmic transformation for rates.

† Variance stabilizing transformations: the arcsine transformation for proportions and square root transformation for rates.

The canonical or the variance stabilizing transformations yield summary proportions (rates) that have to be back-transformed to the raw proportion (rate) scale using the inverse transformation of the respective functions in Table 5. Corresponding back-transformations are needed for the methods that use the discrete likelihood. In the main analyses we simply back-transformed the point estimates and the confidence interval bounds. Because these back-transformations are nonlinear, becomes a skewed distribution in the raw proportion (rate) scale. The back-transformed point estimate is no longer the mean of the back-transformed distribution of the summary proportion (summary rate), and this introduces a bias. In sensitivity analyses we removed this bias by obtaining the mean the back-transformed values using numerical integration. We calculated the performance metrics in Table 1 using both the simple back-transformation, and with numerical integration. Because results were very similar, we report the main analyses in the main text and present the sensitivity analyses in the Appendix.

##### Continuity Correction Factors

When x_j,ik_ = 0 or x_j,ik_ = n_j,k_, the respective proportion was estimated as p˜_j , i k_ = (x_j , i k_ + c)/(n_j , k_ + 2 c) , where c is the continuity correction factor, or correction factor for short. This adjusted estimate p̃_j,ik_ was used in the formulas of Table 5 instead of the unadjusted estimate p_j,ik_ when a continuity correction was needed. Continuity corrections were performed only for pathological studies in a meta-analysis. Since for untransformed proportions, the correction factor is needed only in the variance estimate, we performed two sets of analyses in the untransformed case. The first used p̃_j,ik_ for estimating mean and variance; the second used p_j,ik_ to estimate the mean, but p̃_j,ik_ to estimate the variance. For parsimony and clarity, we present results with the first set of analyses (which is what many meta-analysts have done), and briefly discuss how the second set of analyses differs from the first.

The same discussion applies to rates. In simulated studies with y_j,ik_ = 0 we estimated the respective rate as l˜_j , i k_ = (y_j , i k_ + c)/(e_j , k_ + 2 c) = (c)/(e_j , k_ + 2 c) . Continuity corrections were applied only for pathological studies in a meta-analysis. As for proportions, we run two sets of analyses for methods using untransformed rates: the first used l̃_j,ik_ for estimating mean and variance; the second used l_j,ik_ to estimate the mean, but l̃_j,ik_ to estimate the variance.

#### Discrete Likelihood Methods

We fit discrete likelihood methods by maximizing the likelihood in the generalized linear (mixed) models framework using canonical link functions. We used the R command (package) lmer with a binomial distribution (corresponding to the logit link function); all analyses were checked for correctness by independently coding them in Stata using the xtmelogit command. These methods do not need continuity corrections. For rates, the distribution function in the aforementioned R command is Poisson (whose canonical link function is the log), and the respective Stata command is xtmepoisson. When all (or almost all) simulated studies in a meta-analysis have 0 numerator, the random effects methods may not converge. This can happen when the true proportions or rates are small, the sample sizes or exposure sizes are small, or the number of studies in a meta-analysis is small. For each simulation, we recorded whether the random effects method converged or not. For completeness, we examined a hybrid strategy of attempting to fit a random effects model, and switching to a fixed effect model if the random effects model failed to converge.

The fixed effect model for both proportions and rates is mathematically equivalent to simple pooling, i.e., the summary proportion or the summary rate can be calculated by dividing the sum of the numerators by the sum of the denominators.

### Presentation of Simulation Results

#### Categorizing Simulation Scenarios by Expected Counts per Study

The normal approximation to the binomial is adequate, conservatively, when the expected numbers of events (and no events) is at least 5, i.e., n_j,k_π_j,ik_ > 5 (and n_j,k_(1 − π_j,ik_) > 5). More liberally, one might use a cutoff of 1 event. Hence, for presentation purposes it is sensible to organize the simulated scenarios into 3 categories defined by expected counts of events, namely: those with ≤1; >1 and < 5; and ≥5 expected events per study. For any given scenario, the expected count of events per study is:

expected count_j_ = (π_j_)/(K_j_) ∑_k = 1_^K_j_^ ( n_j k_ )

A similar categorization was used for organizing the simulations on rates, by grouping the scenarios according to the expected number of events in categories with ≤1; between 1 and ≤ 5; and at least 5. The expected number of events is given by a similar formula:

expected count_j_ = (λ_j_)/(K_j_) ∑_k = 1_^K_j_^ ( e_j k_ )