# Discussion

We describe a comprehensive simulation study of a wide range of methods for meta-analysis of proportions and rates. Based on the proportion bias, proportion RMSE and coverage probabilities of the compared methods we make concrete and clear recommendations of immediate relevance to meta-analytic practice. Specifically, we recommend the discrete likelihood methods that model within study data using the binomial likelihood (for proportions) or the Poisson likelihood (for rates) over methods that use normal distributions to approximate within-study variability. If approximate methods must be used (e.g., because there is no access to specialized statistical packages) we recommend using a variance stabilizing transformation, that is, the arcsine for proportions and the square root for rates.

Based on the observations gleaned from this study we conjecture that three major sources of statistical bias have to be dealt with in the meta-analysis of proportions or rates. The first two can be dealt with in a straightforward manner by following the aforementioned recommendations. The third source of statistical bias cannot be dealt with, but we believe that it does not change the recommendations, because it leaves the relative ranking of the available methods unchanged. We expand below.

## Bias Stemming From Continuity Corrections

We have shown clearly that the use of correction factors can introduce arbitrary bias, and degrade RMSE and coverage. Methods necessitating continuity corrections should therefore be avoided when events are rare (or, for proportions, when all units experience an event). The discrete likelihood method (recommendation #1) and the approximate method using the variance stabilizing transformation (recommendation #2) are not susceptible to this limitation.

## Bias Stemming From the Correlation Between Estimate and its Variance

A second source of bias stems from the correlation that is induced between the point estimate and its variance for untransformed or canonically transformed data. Intuitively, this correlation results in a “distortion” of the weights assigned to studies in inverse variance meta-analysis, and this results in a statistical bias. The discrete likelihood method (recommendation #1) is not susceptible to this problem. For approximate methods, the variance stabilizing transformation (recommendation #2) removes the correlation between estimates and their variance, and corrects the statistical bias.

Note that this bias is not limited to rare event situations, but applies throughout the range of proportions or rates. Indeed, we found clear differences between the three approximate methods in the proportion bias, proportion RMSE and coverage probabilities, with the variance stabilizing transformations being preferable. In a limited simulation study comparing the discrete likelihood method with the canonical transformation for the meta-analysis of proportions, Hamza et al. conjectured that all approximate methods would have comparably large bias, because “there will always be a correlation between the estimate and the within-study variance, as they are determined by the same parameter […]”.6 Hamza et al. did not recognize the arcsine transformation as a variance stabilizing one, i.e., one that does not suffer from the bias induced by the correlation between the estimates of the proportion (or rate) and the variance.

## Bias Stemming From a Misspecification of the Random Effects Distribution

Finally, the third source of bias stems from the fact that the true random effects distribution of the proportions or rates is unknown. Meta-analysis models that assume a random effects distribution other than the true will introduce some statistical bias. The more extreme the departure of the assumed random effects distribution from the true one, the greater the bias. Because the true distribution is unknowable, it is impossible to eliminate this bias. Instead, one can examine the relative performance of meta-analysis methods in data simulated using alternative random effects distributions. General recommendations are feasible when the relative ranking of the methods is stable across the simulated random effects distributions. We simulated beta and uniform distributions in the proportion scale and (gamma and uniform distributions for rates). Excluding the approximate methods that use untransformed data, the other meta-analysis methods make calculations in a transformed scale (i.e., using the logit() or the arcsin(sqrt()) transformation for proportions, and the log() and sqrt() transformation for rates).^j^

j Note that this holds for the discrete likelihood methods as well: for proportions, the link function is the logit() and for rates the log().

All these functions are concave for proportions between 0, 0.50, and therefore introduce a negative bias: The mean in the transformed scale will be smaller than the transformation of the mean in the proportion scale. For concreteness, consider that the true proportion is 0.10 and that the square root of the heterogeneity parameter is 0.05 (large heterogeneity). These values correspond to a Beta(3.5, 31.5). The mean of the logit transformation of this Beta is -2.331 (by numerical Monte Carlo integration), which corresponds to 0.089 in the proportion scale, a -11 percent proportion bias. Using a uniform distribution instead of a beta yields a similar bias. The specific distribution would be a Uniform(0.0134, 0.1866), and the mean of its logit-transformed values is -2.368, which corresponds to 0.086 in the proportion scale, and a proportion bias of -14 percent. If one were using the variance stabilizing transformation, which is less “drastic”^k^, the statistical bias is smaller: -2.6 percent for the beta, and -3.4 percent for the uniform.

k For proportions between 0 and 0.50, the first derivatives of the logit() and arcsine(sqrt()) transformations are both negative, but that of the logit is strictly smaller (more extreme). Because the statistical bias is determined by the first derivative of the transformations, it is more extreme for the canonical (former) compared to the variance stabilizing (latter) transformation. Because 0.50 is an inflection point for both transformations, there is no bias for mean proportions of 0.50.

The canonical and variance stabilizing transformations for proportions are point-symmetric around 0.50. Thus, they have no bias at exactly 0.50, and have a positive bias above 0.50. In our simulations we observed that for true proportions equal to 0.50, the bias with the canonical and variance stabilizing transformations is almost zero.

The analogous applies to rates. However, the canonical and variance-stabilizing transformations for rates are strictly concave, and therefore have a negative bias throughout the positive domain, which diminishes as the expected number of events rises.

As discussed above, the bias introduced by the potential misspecification of the true random effects distribution in the meta-analysis affects meta-analysis methods using canonical and variance-stabilizing transformations, as well as the discrete likelihood methods in a similar manner. We conjecture that for many forms of sampling distributions the relative ordering of the methods with respect to proportion bias and RMSE and coverage will remain relatively stable. Therefore, the recommendations #1 and #2 above are reasonable in general. For example, Hamza et al.6 assumed a log normal distribution for the random effects, which removes the third type of bias, as it matches the analysis methods exactly. Hamza et al. showed that the discrete likelihood method outperforms the approximate method using the canonical link (presumably because of the two other biases),6 which is in accordance to our first recommendation.

We find it encouraging that our results (which focus on the summary proportion) did not seem to depend on the form of the distribution for proportions simulated: results were very consistent between scenarios using the uniform or the beta (gamma) distribution. This is not surprising given the above discussion. Further, it may be that the number of studies in our simulation study was small enough that —so long as the standard deviation is the same—it does not make a difference whether they were generated by a uniform or by a beta (or gamma). The shape of the distribution may have a large impact on the statistical properties of the heterogeneity estimator with each method. However, we did not focus on this aspect, which is reserved for future work.

## Other Considerations

The recommended discrete likelihood methods are straightforward to fit in the familiar generalized linear mixed models (GLMM) framework. Meta-analysts who are not statistically sophisticated and are not familiar with statistical programming environments such as R, Stata or SAS will probably be challenged to follow our primary recommendation. First, most of these environments do not have an elaborate point-and-click interface, and some programming may be needed. Second, GLMM software routines can be unstable, and the default options may need adjustment to ensure convergence of the fitting algorithm. Specifically, to evaluate the log likelihood of a GLMM is it necessary to perform a numerical integration step.22 The numerical integration is achieved by quadrature or adaptive quadrature algorithms, which become more precise (and more computationally expensive, i.e., slow) when they use more integration points. It is good practice to examine the robustness of the results using increasing number of integration points (e.g., 8, 12, 16, 20, 25).10-12 The estimate of the between-study variance rather than the estimate of the summary proportion is more sensitive to the number of integration points.11

So what should one do if the GLMM algorithm does not converge? In our experience, non-convergence can be an issue if all or almost all studies have 0 in the numerators of the proportions or rates. Increasing the number of integration points does not necessarily fix the problem. When this happens, we propose to perform a meta-analysis using the discrete likelihood and fixed effects, or the approximate method with the variance stabilizing transformation as a secondary approach.

As of this writing, none of the standalone meta-analysis packages performs GLMM-based meta-analysis of proportions or rates,13,14,23 despite the fact that it can be very easily added in those with a modular open source architecture such as OpenMeta-Analyst.14 Therefore, the second recommendation to use a variance stabilizing transformation is important, as it is very easy to implement even in a spreadsheet program such as Microsoft Excel ™.

In sum, we believe that enough information exists to provide strong guidance on the performance characteristics of alternative methods for the meta-analysis of proportions and rates. While differences between the approximate and the discrete likelihood methods attenuate when the expected count is larger than 5, i.e., when the sample sizes or the exposures are large and the proportions/rates are not close to zero, it is probably best to avoid analyses of untransformed or logit proportions. Analysts experienced with programming and GLMMs should prefer the discrete likelihood methods. When these fail or when the analyst is not experienced enough to use them, the variance stabilizing transformations will usually offer a safe alternative since many meta-analyses will have large enough expected counts and rates. Only if sufficient data are available and other options are not practical, should untransformed or logit proportions be used.