# Background

Meta-analyses of proportions or rates (e.g., incidence rates) are very often included in reports generated by the Effective Health Care Program, and in systematic reviews in general. For example, one would use a meta-analysis of proportions to calculate the summary frequency of adverse or harmful events. Depending on the clinical context, adverse events can be rare (e.g., the incidence rate of rhabdomyolysis in statin treated patients is approximately 3.3 events per 100,000 patient years1) or quite common (e.g., the average percentage of nausea and vomiting in chemotherapy-treated cancer patients was 48 percent in a meta-analysis of randomized trials2). Meta-analysis of proportions can also be applied to evaluate medical test performance. Although a bivariate meta-analysis of sensitivity and specificity or summarization with a hierarchical summary operating characteristic curve is commonly recommended, separate (univariate) meta-analyses may be sufficient when there is little variation in either sensitivity or specificity.3,4

Assuming that it is appropriate to perform a meta-analysis of proportions or rates, many open questions remain about which statistical methods are best to use. Generally speaking, we can group meta-analytic approaches into two families according to how they model within-study variability:

1. Discrete likelihood methods, which model the proportion of events or the incidence rate in a study using the binomial or Poisson distribution, respectively. These are theoretically motivated choices.
2. Approximate methods, which approximate within-study variability with a normal distribution. Of the many variants that have been used, the three that are most interesting^a^ use a normal distribution to approximate the distribution of:
  a Because they have been used commonly, or for theoretical reasons – see later paragraphs.
  a. Untransformed proportions or rates.
  b. Canonical transformations for proportions (logit transformations) and rates (logarithmic transformations).^b^
    b These are termed “canonical” as they are the typical transformations for the binomial and Poisson families in the framework of Generalized Linear Models. See McCullough P, Nelder JA. Generalized linear models. 2 ed. Chapman & Hall. 1989.
  c. Variance stabilizing transformations for proportions (arcsine transformations) and rates (square root transformations).^c^
    c Variance stabilizing transformations are discussed in Chapter 15 of Snedecor GW, Cochran WG. Statistical methods. 7ed. Ames. The Iowa State University Press. 1980.

The approximate methods have known shortcomings. First, they rely on the normal approximation to the binomial or Poisson distributions, which may introduce a bias or have other poor statistical properties when the proportion or rate is close to zero (or one), or when the study sample sizes are relatively small. Both situations are not uncommon in practice. A way to reduce this bias in the extremes (near zero or one) is to use the “canonical” transformations of proportions and rates. Intuitively, these non-linear transformations change the “spacing” of proportions and rates near the extremes. The logit transformation for proportions “expands” values near zero or one (mapping them to the whole real axis) and the logarithmic transformation for rates “expands” values tending to zero (rates are typically small numbers).

A second problem is that, for untransformed and canonically transformed proportions and rates, the sample variance is a function of, and is therefore correlated with, the sample mean. Failure to account for this correlation in the model may bias the summary estimate and its variance.5-7 Corrections for this bias have been proposed,5 but are not used in practice.6,8 Alternatively, variance stabilizing transformations, i.e., transformations for which the variance is independent of the estimated mean (arcsine transformations for proportions and square root transformations for rates) are a standard fix for the bias induced by this correlation.9

Discrete likelihood methods for random effects are fit as generalized linear mixed (GLMM) models,7 (e.g., as random effects logistic or Poisson regressions). They cannot be implemented with non-iterative methods in simple spreadsheets,^d^ and require programming in a general statistical package such as Stata, R, or SAS. While straightforward to implement for those with solid understanding of GLMMs and statistical languages, they are not easily accessible to meta-analysts without programming skills. Moreover, the routines that fit the discrete likelihood methods use numerical integration algorithms10 that require examination of the robustness of the results to the algorithms' default settings.^e,11,12^ These algorithms can also fail to converge. Inexperienced users may be unable to properly assess and cope with these complexities. As of this writing, no stand-alone meta-analysis software implements GLMMs for meta-analysis of binary data, including the meta-analysis of proportions.13,14 Therefore, unless the discrete likelihood methods are substantially better than the approximate methods, it is unlikely they will be heavily used.

d Such as MS Excel™.

e Specifically, one has to check the sensitivity of the quadrature or adaptive quadrature method for numerically integrating the likelihood during model fit. Typically, one increases the number of integration points used by the algorithm (which results in slower but more accurate calculations) and checks for any numerical differences in the results.

So which of the above methods should one prefer? A satisfactory answer to this question cannot be a purely empirical one. For example, it cannot be obtained by contrasting these methods in a large number of real-life datasets, because there is no way to know which method is closer to the unobserved “truth.” The best approach is to perform a comprehensive simulation study.

We describe an extensive simulation study to assess the statistical properties of the above approaches to meta-analysis of proportions and incidence rates. This study is much broader than previous related investigations. For instance, several large simulation studies have extensively explored different methods for analyzing proportions,15-18 but did not address meta-analysis across studies. Several others have investigated meta-analysis of proportions,6 but did not compare all of the above methods in a wide range of realistic simulation scenarios. Stijnen et al19 discussed the Poisson-normal random effects model for rates, but did no simulations. However, they do provide example SAS code for the discrete likelihood methods.