# Additional Descriptions of Methods and Results

Table A-1 Sample Sizes Used in Simulations for Proportions

| Small | Heterogeneity Medium | Large | Mixed
5 Studies | 41 50 33 26 21 | 120 69 161 154 138 | 339 974 619 675 576 | 26 9 109 63 887
15 Studies | 32 28 15 30 6 46 45 33 21 29 26 20 19 44 11 | 176 78 152 85 60 92 73 55 126 164 113 126 138 165 118 | 655 326 815 889 991 373 262 565 956 245 701 282 881 810 676 | 46 42 21 16 35 26 32 83 197 119 198 100 58 241 794
30 Studies | 20 23 22 15 8 13 27 11 38 48 44 31 50 40 33 45 43 16 8 34 42 35 24 29 31 30 5 20 21 13 | 60 71 153 184 183 105 99 145 112 59 153 59 90 70 154 134 124 176 59 66 104 94 75 66 117 62 144 113 132 62 | 270 626 212 267 760 217 659 946 547 884 829 342 680 261 272 206 259 440 906 717 234 421 772 714 477 512 529 640 900 958 | 43 36 49 11 27 5 18 14 31 27 50 47 9 50 12 157 199 178 91 121 173 107 181 155 169 120 186 441 324 782

These vectors were drawn randomly and then kept fixed throughout the simulations.

Table A-2 Sample Sizes Used in Simulations for Rates

Number of studies | Small | Heterogeneity Medium | Large | Mixed
K=5 | 170 199 142 120 104 | 339 237 421 407 375 | 2143 9686 5469 6137 4961 | 120 64 317 226 8652
K=15 | 138 125 84 132 53 186 181 142 102 130 120 100 99 180 72 | 452 256 403 269 220 284 245 210 352 427 325 352 375 429 336 | 5893 1994 7792 8674 9889 2552 1232 4823 9467 1025 6443 1463 8575 7733 6143 | 187 171 102 86 149 119 139 265 494 338 495 299 216 977 7549
K=30 | 101 110 107 85 62 79 123 71 161 193 178 138 198 165 142 184 176 87 61 145 173 148 114 129 136 132 52 100 105 77 | 220 242 405 467 466 309 297 389 323 218 406 217 280 240 407 367 348 452 218 231 308 288 249 231 334 223 388 326 363 223 | 1330 5551 633 1284 7146 691 5941 9358 4609 8613 7966 2180 6198 1220 1353 561 1194 3349 8876 6638 903 3120 7281 6598 3785 4205 4399 5724 8807 9493 | 175 151 197 70 125 50 95 82 138 124 199 189 64 197 73 414 497 455 281 342 446 314 461 409 437 339 471 3353 1967 7399

These vectors were drawn randomly and then kept fixed throughout the simulations.

Table A-3 Formulas for setting the parameters of beta, uniform and gamma distributions

Parameters for the distribution of the true effects in simulations | Explanations for simulations of proportions and rates | Formulas for the first parameter | Formulas for the second parameter
Beta: parameters α and β | For proportions, set μ = π_j_, and σ = τ_j_π_j_ For rates: Not applicable | α = ( 1 − μ ) ( (μ)/(σ) )^2^ − μ | β = (1 − μ)/(μ) α
Uniform: bounds [a, b] | For proportions, set μ = π_j_, and σ = τ_j_π_j_ For rates, set μ = λ_j_, and σ = τ_j_λ_j_ | α = μ − sqrt(3) σ | b = μ + sqrt(3) σ
Gamma: parameters α and β | For proportions: Not applicable For rates, set μ = λ_j_ and σ = τ_j_λ_j_ | α = ( (μ)/(σ) )^2^ | β = ((σ)/(μ))^2^

In the above, j indexes the simulation scenario. As described in the methods, the standard deviation of the true effects is parameterized as a multiplier on the magnitude of the true proportion or rate. When τ_j_ = 0 the above distributions are not used and all simulated studies have the same true effect (see Methods).

Table A-4 Comparison of proportion bias across random effects methods (selected scenarios with zero heterogeneity)

Scenario | K | Proportion | Sample size | Exp count | Approximate untransformed | Approximate logit | Approximate arcsine | Discrete (fraction converged) | Discrete (random) | Discrete (hybrid)
S1 | 5 | 0.001 | small | <0.1 | 12.422 | 14.531 | -0.733 | 0.168 | 5.039 | 0.015
M1 | 5 | 0.001 | medium | 0.1 | 2.946 | 3.700 | -0.680 | 0.482 | 0.947 | -0.061
S2 | 5 | 0.005 | small | 0.2 | 1.949 | 2.698 | -0.635 | 0.569 | 0.646 | -0.064
X1 | 5 | 0.001 | mixed | 0.2 | 0.421 | 6.042 | -0.258 | 0.652 | 0.467 | -0.043
S3 | 5 | 0.01 | small | 0.3 | 0.656 | 1.233 | -0.557 | 0.818 | 0.109 | -0.093
L1 | 5 | 0.001 | large | 0.6 | 0.118 | 0.663 | -0.401 | 0.956 | -0.001 | -0.045
M2 | 5 | 0.005 | medium | 0.6 | 0.080 | 0.605 | -0.436 | 0.956 | -0.049 | -0.091
X2 | 5 | 0.005 | mixed | 1.1 | 0.061 | 0.743 | -0.202 | 0.994 | 0.022 | 0.016
M3 | 5 | 0.01 | medium | 1.3 | -0.189 | 0.288 | -0.262 | 0.997 | -0.043 | -0.046
S4 | 5 | 0.05 | small | 1.7 | -0.191 | 0.200 | -0.173 | 1.000 | -0.026 | -0.026
X3 | 5 | 0.01 | mixed | 2.2 | -0.005 | 0.318 | -0.223 | 1.000 | 0.016 | 0.016
L2 | 5 | 0.005 | large | 3.2 | -0.184 | 0.094 | -0.108 | 1.000 | -0.032 | -0.032
S5 | 5 | 0.1 | small | 3.4 | -0.132 | 0.083 | -0.065 | 1.000 | -0.011 | -0.011
L3 | 5 | 0.01 | large | 6.4 | -0.113 | 0.026 | -0.058 | 1.000 | -0.029 | -0.029
M4 | 5 | 0.05 | medium | 6.4 | -0.083 | 0.043 | -0.032 | 1.000 | -0.007 | -0.007
X4 | 5 | 0.05 | mixed | 10.9 | -0.056 | 0.063 | -0.080 | 1.000 | 0.003 | 0.003
M5 | 5 | 0.1 | medium | 12.8 | -0.032 | 0.021 | -0.007 | 1.000 | 0.002 | 0.002
S6 | 5 | 0.4 | small | 13.7 | -0.009 | 0.004 | -0.003 | 1.000 | -0.001 | -0.001
S7 | 5 | 0.5 | small | 17.1 | -0.001 | -0.001 | -0.001 | 1.000 | -0.001 | -0.001
X5 | 5 | 0.1 | mixed | 21.9 | -0.045 | 0.025 | -0.043 | 1.000 | -0.001 | -0.001
L4 | 5 | 0.05 | large | 31.8 | -0.017 | 0.007 | -0.005 | 0.998 | -0.001 | -0.001
M6 | 5 | 0.4 | medium | 51.4 | -0.002 | 0.001 | -0.001 | 1.000 | 0.000 | 0.000
L5 | 5 | 0.1 | large | 63.7 | -0.007 | 0.003 | -0.002 | 1.000 | 0.000 | 0.000
M7 | 5 | 0.5 | medium | 64.2 | -0.001 | -0.001 | -0.001 | 1.000 | -0.001 | -0.001
X6 | 5 | 0.4 | mixed | 87.5 | -0.006 | 0.002 | -0.002 | 1.000 | -0.001 | -0.001
X7 | 5 | 0.5 | mixed | 109.4 | -0.001 | -0.001 | -0.001 | 1.000 | -0.001 | -0.001
L6 | 5 | 0.4 | large | 254.6 | 0.001 | 0.001 | 0.001 | 0.999 | 0.001 | 0.001
L7 | 5 | 0.5 | large | 318.3 | 0.001 | 0.001 | 0.001 | 0.998 | 0.001 | 0.001
S1 | 15 | 0.001 | small | <0.1 | 14.550 | 19.530 | -0.887 | 0.336 | 0.456 | -0.511
M1 | 15 | 0.001 | medium | 0.1 | 3.192 | 4.308 | -0.815 | 0.808 | -0.106 | -0.278
X1 | 15 | 0.001 | mixed | 0.1 | 0.986 | 5.984 | -0.634 | 0.864 | -0.039 | -0.169
S2 | 15 | 0.005 | small | 0.1 | 2.366 | 3.687 | -0.784 | 0.875 | -0.120 | -0.230
S3 | 15 | 0.01 | small | 0.3 | 0.851 | 1.747 | -0.678 | 0.982 | -0.131 | -0.146
M2 | 15 | 0.005 | medium | 0.6 | 0.117 | 0.775 | -0.520 | 0.999 | -0.072 | -0.072
L1 | 15 | 0.001 | large | 0.6 | 0.017 | 0.741 | -0.505 | 1.000 | -0.084 | -0.084
X2 | 15 | 0.005 | mixed | 0.7 | 0.001 | 0.886 | -0.402 | 1.000 | -0.037 | -0.037
M3 | 15 | 0.01 | medium | 1.1 | -0.215 | 0.390 | -0.321 | 0.999 | -0.033 | -0.032
X3 | 15 | 0.01 | mixed | 1.3 | -0.134 | 0.388 | -0.295 | 1.000 | -0.016 | -0.016
S4 | 15 | 0.05 | small | 1.4 | -0.250 | 0.302 | -0.272 | 1.000 | -0.036 | -0.036
S5 | 15 | 0.1 | small | 2.7 | -0.205 | 0.137 | -0.109 | 1.000 | -0.014 | -0.014
L2 | 15 | 0.005 | large | 3.1 | -0.228 | 0.137 | -0.119 | 0.999 | -0.021 | -0.021
M4 | 15 | 0.05 | medium | 5.7 | -0.127 | 0.070 | -0.045 | 1.000 | -0.006 | -0.006
L3 | 15 | 0.01 | large | 6.3 | -0.128 | 0.067 | -0.046 | 0.999 | -0.006 | -0.006
X4 | 15 | 0.05 | mixed | 6.7 | -0.118 | 0.061 | -0.086 | 0.999 | -0.010 | -0.010
S6 | 15 | 0.4 | small | 10.8 | -0.014 | 0.011 | -0.003 | 0.998 | 0.002 | 0.002
M5 | 15 | 0.1 | medium | 11.5 | -0.057 | 0.028 | -0.018 | 0.999 | -0.003 | -0.003
X5 | 15 | 0.1 | mixed | 13.4 | -0.069 | 0.033 | -0.026 | 1.000 | 0.001 | 0.001
S7 | 15 | 0.5 | small | 13.5 | 0.000 | 0.000 | 0.000 | 1.000 | 0.000 | 0.000
L4 | 15 | 0.05 | large | 31.4 | -0.024 | 0.011 | -0.006 | 0.994 | -0.001 | -0.001
M6 | 15 | 0.4 | medium | 45.9 | -0.003 | 0.002 | -0.001 | 0.997 | 0.000 | 0.000
X6 | 15 | 0.4 | mixed | 53.5 | -0.005 | 0.002 | -0.001 | 0.998 | 0.000 | 0.000
M7 | 15 | 0.5 | medium | 57.4 | 0.001 | 0.001 | 0.001 | 0.996 | 0.001 | 0.001
L5 | 15 | 0.1 | large | 62.8 | -0.010 | 0.006 | -0.002 | 0.993 | 0.000 | 0.000
X7 | 15 | 0.5 | mixed | 66.9 | 0.000 | 0.000 | 0.000 | 0.999 | 0.000 | 0.000
L6 | 15 | 0.4 | large | 251.4 | 0.000 | 0.000 | 0.000 | 0.996 | 0.000 | 0.000
L7 | 15 | 0.5 | large | 314.2 | 0.000 | 0.000 | 0.000 | 0.985 | 0.000 | 0.000
S1 | 30 | 0.001 | small | <0.1 | 14.013 | 19.620 | -0.937 | 0.537 | -0.684 | -0.830
M1 | 30 | 0.001 | medium | 0.1 | 3.346 | 4.654 | -0.854 | 0.949 | -0.333 | -0.367
X1 | 30 | 0.001 | mixed | 0.1 | 1.114 | 6.593 | -0.733 | 0.979 | -0.200 | -0.217
S2 | 30 | 0.005 | small | 0.1 | 2.248 | 3.701 | -0.823 | 0.983 | -0.278 | -0.291
S3 | 30 | 0.01 | small | 0.3 | 0.793 | 1.771 | -0.696 | 1.000 | -0.130 | -0.130
M2 | 30 | 0.005 | medium | 0.5 | 0.141 | 0.846 | -0.561 | 1.000 | -0.071 | -0.071
L1 | 30 | 0.001 | large | 0.5 | 0.101 | 0.864 | -0.542 | 1.000 | -0.059 | -0.059
X2 | 30 | 0.005 | mixed | 0.6 | -0.081 | 1.021 | -0.418 | 1.000 | -0.043 | -0.043
M3 | 30 | 0.01 | medium | 1.1 | -0.210 | 0.419 | -0.360 | 0.998 | -0.037 | -0.037
X3 | 30 | 0.01 | mixed | 1.3 | -0.193 | 0.456 | -0.274 | 0.998 | -0.009 | -0.010
S4 | 30 | 0.05 | small | 1.4 | -0.263 | 0.310 | -0.275 | 1.000 | -0.027 | -0.027
S5 | 30 | 0.1 | small | 2.7 | -0.221 | 0.150 | -0.115 | 0.999 | -0.008 | -0.008
L2 | 30 | 0.005 | large | 2.7 | -0.264 | 0.182 | -0.138 | 1.000 | -0.012 | -0.012
M4 | 30 | 0.05 | medium | 5.4 | -0.149 | 0.082 | -0.051 | 0.999 | -0.006 | -0.006
L3 | 30 | 0.01 | large | 5.5 | -0.162 | 0.081 | -0.063 | 0.998 | -0.011 | -0.011
X4 | 30 | 0.05 | mixed | 6.4 | -0.110 | 0.065 | -0.069 | 1.000 | -0.007 | -0.007
M5 | 30 | 0.1 | medium | 10.8 | -0.069 | 0.032 | -0.021 | 1.000 | -0.004 | -0.004
S6 | 30 | 0.4 | small | 10.9 | -0.017 | 0.009 | -0.005 | 0.998 | 0.000 | 0.000
X5 | 30 | 0.1 | mixed | 12.7 | -0.063 | 0.030 | -0.027 | 0.998 | -0.001 | -0.001
S7 | 30 | 0.5 | small | 13.6 | -0.002 | -0.002 | -0.002 | 1.000 | -0.002 | -0.002
L4 | 30 | 0.05 | large | 27.4 | -0.030 | 0.014 | -0.008 | 0.993 | -0.001 | -0.001
M6 | 30 | 0.4 | medium | 43.0 | -0.002 | 0.004 | 0.001 | 0.997 | 0.002 | 0.002
X6 | 30 | 0.4 | mixed | 50.8 | -0.004 | 0.003 | 0.000 | 0.997 | 0.001 | 0.001
M7 | 30 | 0.5 | medium | 53.8 | 0.000 | 0.000 | 0.000 | 0.999 | 0.000 | 0.000
L5 | 30 | 0.1 | large | 54.9 | -0.013 | 0.006 | -0.003 | 0.988 | 0.000 | 0.000
X7 | 30 | 0.5 | mixed | 63.5 | 0.000 | 0.000 | 0.000 | 0.997 | 0.000 | 0.000
L6 | 30 | 0.4 | large | 219.4 | 0.000 | 0.001 | 0.000 | 0.992 | 0.001 | 0.001
L7 | 30 | 0.5 | large | 274.3 | 0.000 | 0.000 | 0.000 | 0.986 | 0.000 | 0.000

“Discrete” stands for discrete likelihood methods. Scenarios are ordered by number of studies (K), and then by expected count. Bold horizontal lines separate scenarios by number of studies. White and grey shading separates scenarios with expected counts ≤1, between 1 and 5, and ≥5. We code scenarios using two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1, 6=0.4, 7=0.5).

The column “Discrete (fraction converged)” shows the proportion of simulations for which random effects methods converged successfully. Values of 1.000 mean that random effects methods converged successfully in all 1000 simulations in a scenario, and a value of e.g., 0.335 means that they converged in 335 out of 1000 simulations in a scenario. The columns “Discrete (random)” and “Discrete (hybrid)” are identical when the fraction converged is 1.000, because the random effects method was used in all simulations.

Table A-5 Comparison of proportion RMSE across random effects methods (selected scenarios with zero heterogeneity)

Scenario | K | Proportion | Sample size | Exp count | Approximate untransformed | Approximate logit | Approximate arcsine | Discrete (fraction converged) | Discrete (random) | Discrete (hybrid)
S1 | 5 | 0.001 | small | <0.1 | 12.454 | 14.629 | 1.034 | 0.168 | 5.336 | 2.370
M1 | 5 | 0.001 | medium | 0.1 | 2.978 | 3.813 | 0.882 | 0.482 | 1.350 | 1.182
S2 | 5 | 0.005 | small | 0.2 | 1.999 | 2.847 | 0.850 | 0.569 | 1.111 | 1.064
X1 | 5 | 0.001 | mixed | 0.2 | 1.020 | 6.099 | 0.846 | 0.652 | 0.985 | 0.990
S3 | 5 | 0.01 | small | 0.3 | 0.732 | 1.406 | 0.743 | 0.818 | 0.661 | 0.734
L1 | 5 | 0.001 | large | 0.6 | 0.329 | 0.873 | 0.644 | 0.956 | 0.562 | 0.588
M2 | 5 | 0.005 | medium | 0.6 | 0.286 | 0.827 | 0.649 | 0.956 | 0.544 | 0.572
X2 | 5 | 0.005 | mixed | 1.1 | 0.436 | 0.898 | 0.450 | 0.994 | 0.438 | 0.444
M3 | 5 | 0.01 | medium | 1.3 | 0.329 | 0.500 | 0.477 | 0.997 | 0.400 | 0.403
S4 | 5 | 0.05 | small | 1.7 | 0.342 | 0.400 | 0.413 | 1.000 | 0.355 | 0.355
X3 | 5 | 0.01 | mixed | 2.2 | 0.290 | 0.478 | 0.418 | 1.000 | 0.313 | 0.313
L2 | 5 | 0.005 | large | 3.2 | 0.309 | 0.271 | 0.297 | 1.000 | 0.260 | 0.260
S5 | 5 | 0.1 | small | 3.4 | 0.269 | 0.241 | 0.257 | 1.000 | 0.234 | 0.234
L3 | 5 | 0.01 | large | 6.4 | 0.212 | 0.176 | 0.193 | 1.000 | 0.180 | 0.180
M4 | 5 | 0.05 | medium | 6.4 | 0.197 | 0.178 | 0.181 | 1.000 | 0.175 | 0.175
X4 | 5 | 0.05 | mixed | 10.9 | 0.167 | 0.179 | 0.220 | 1.000 | 0.153 | 0.153
M5 | 5 | 0.1 | medium | 12.8 | 0.128 | 0.121 | 0.122 | 1.000 | 0.121 | 0.121
S6 | 5 | 0.4 | small | 13.7 | 0.100 | 0.094 | 0.097 | 1.000 | 0.096 | 0.096
S7 | 5 | 0.5 | small | 17.1 | 0.080 | 0.076 | 0.078 | 1.000 | 0.077 | 0.077
X5 | 5 | 0.1 | mixed | 21.9 | 0.125 | 0.109 | 0.146 | 1.000 | 0.103 | 0.103
L4 | 5 | 0.05 | large | 31.8 | 0.079 | 0.077 | 0.077 | 0.998 | 0.077 | 0.077
M6 | 5 | 0.4 | medium | 51.4 | 0.049 | 0.048 | 0.049 | 1.000 | 0.048 | 0.048
L5 | 5 | 0.1 | large | 63.7 | 0.053 | 0.053 | 0.053 | 1.000 | 0.053 | 0.053
M7 | 5 | 0.5 | medium | 64.2 | 0.039 | 0.039 | 0.039 | 1.000 | 0.039 | 0.039
X6 | 5 | 0.4 | mixed | 87.5 | 0.052 | 0.043 | 0.047 | 1.000 | 0.041 | 0.041
X7 | 5 | 0.5 | mixed | 109.4 | 0.044 | 0.036 | 0.038 | 1.000 | 0.034 | 0.034
L6 | 5 | 0.4 | large | 254.6 | 0.023 | 0.023 | 0.023 | 0.999 | 0.022 | 0.022
L7 | 5 | 0.5 | large | 318.3 | 0.018 | 0.018 | 0.018 | 0.998 | 0.017 | 0.017
S1 | 15 | 0.001 | small | <0.1 | 14.561 | 19.564 | 0.931 | 0.336 | 1.877 | 1.359
M1 | 15 | 0.001 | medium | 0.1 | 3.203 | 4.356 | 0.849 | 0.808 | 0.823 | 0.860
X1 | 15 | 0.001 | mixed | 0.1 | 1.272 | 6.021 | 0.747 | 0.864 | 0.728 | 0.771
S2 | 15 | 0.005 | small | 0.1 | 2.381 | 3.733 | 0.824 | 0.875 | 0.740 | 0.777
S3 | 15 | 0.01 | small | 0.3 | 0.877 | 1.811 | 0.734 | 0.982 | 0.560 | 0.571
M2 | 15 | 0.005 | medium | 0.6 | 0.194 | 0.856 | 0.586 | 0.999 | 0.377 | 0.377
L1 | 15 | 0.001 | large | 0.6 | 0.153 | 0.812 | 0.568 | 1.000 | 0.349 | 0.349
X2 | 15 | 0.005 | mixed | 0.7 | 0.288 | 0.934 | 0.481 | 1.000 | 0.332 | 0.332
M3 | 15 | 0.01 | medium | 1.1 | 0.261 | 0.471 | 0.405 | 0.999 | 0.253 | 0.253
X3 | 15 | 0.01 | mixed | 1.3 | 0.246 | 0.454 | 0.376 | 1.000 | 0.235 | 0.235
S4 | 15 | 0.05 | small | 1.4 | 0.297 | 0.378 | 0.361 | 1.000 | 0.229 | 0.229
S5 | 15 | 0.1 | small | 2.7 | 0.255 | 0.200 | 0.199 | 1.000 | 0.154 | 0.154
L2 | 15 | 0.005 | large | 3.1 | 0.270 | 0.205 | 0.197 | 0.999 | 0.151 | 0.151
M4 | 15 | 0.05 | medium | 5.7 | 0.170 | 0.128 | 0.122 | 1.000 | 0.109 | 0.109
L3 | 15 | 0.01 | large | 6.3 | 0.164 | 0.120 | 0.114 | 0.999 | 0.100 | 0.100
X4 | 15 | 0.05 | mixed | 6.7 | 0.155 | 0.120 | 0.150 | 0.999 | 0.101 | 0.101
S6 | 15 | 0.4 | small | 10.8 | 0.069 | 0.060 | 0.063 | 0.998 | 0.061 | 0.061
M5 | 15 | 0.1 | medium | 11.5 | 0.095 | 0.077 | 0.077 | 0.999 | 0.074 | 0.074
X5 | 15 | 0.1 | mixed | 13.4 | 0.105 | 0.078 | 0.084 | 1.000 | 0.071 | 0.071
S7 | 15 | 0.5 | small | 13.5 | 0.054 | 0.049 | 0.051 | 1.000 | 0.050 | 0.050
L4 | 15 | 0.05 | large | 31.4 | 0.052 | 0.047 | 0.046 | 0.994 | 0.045 | 0.045
M6 | 15 | 0.4 | medium | 45.9 | 0.030 | 0.029 | 0.029 | 0.997 | 0.029 | 0.029
X6 | 15 | 0.4 | mixed | 53.5 | 0.031 | 0.028 | 0.029 | 0.998 | 0.028 | 0.028
M7 | 15 | 0.5 | medium | 57.4 | 0.024 | 0.024 | 0.024 | 0.996 | 0.024 | 0.024
L5 | 15 | 0.1 | large | 62.8 | 0.033 | 0.032 | 0.031 | 0.993 | 0.031 | 0.031
X7 | 15 | 0.5 | mixed | 66.9 | 0.023 | 0.022 | 0.023 | 0.999 | 0.022 | 0.022
L6 | 15 | 0.4 | large | 251.4 | 0.013 | 0.012 | 0.012 | 0.996 | 0.012 | 0.012
L7 | 15 | 0.5 | large | 314.2 | 0.010 | 0.010 | 0.010 | 0.985 | 0.010 | 0.010
S1 | 30 | 0.001 | small | <0.1 | 14.017 | 19.637 | 0.944 | 0.537 | 0.993 | 0.996
M1 | 30 | 0.001 | medium | 0.1 | 3.352 | 4.677 | 0.867 | 0.949 | 0.759 | 0.773
X1 | 30 | 0.001 | mixed | 0.1 | 1.212 | 6.610 | 0.766 | 0.979 | 0.588 | 0.599
S2 | 30 | 0.005 | small | 0.1 | 2.254 | 3.723 | 0.836 | 0.983 | 0.633 | 0.641
S3 | 30 | 0.01 | small | 0.3 | 0.806 | 1.799 | 0.722 | 1.000 | 0.432 | 0.432
M2 | 30 | 0.005 | medium | 0.5 | 0.181 | 0.888 | 0.591 | 1.000 | 0.280 | 0.280
L1 | 30 | 0.001 | large | 0.5 | 0.158 | 0.903 | 0.574 | 1.000 | 0.278 | 0.278
X2 | 30 | 0.005 | mixed | 0.6 | 0.227 | 1.047 | 0.468 | 1.000 | 0.259 | 0.259
M3 | 30 | 0.01 | medium | 1.1 | 0.236 | 0.466 | 0.404 | 0.998 | 0.198 | 0.198
X3 | 30 | 0.01 | mixed | 1.3 | 0.244 | 0.484 | 0.325 | 0.998 | 0.168 | 0.169
S4 | 30 | 0.05 | small | 1.4 | 0.287 | 0.352 | 0.321 | 1.000 | 0.165 | 0.165
S5 | 30 | 0.1 | small | 2.7 | 0.245 | 0.182 | 0.163 | 0.999 | 0.105 | 0.105
L2 | 30 | 0.005 | large | 2.7 | 0.286 | 0.216 | 0.185 | 1.000 | 0.114 | 0.114
M4 | 30 | 0.05 | medium | 5.4 | 0.169 | 0.113 | 0.096 | 0.999 | 0.079 | 0.079
L3 | 30 | 0.01 | large | 5.5 | 0.180 | 0.113 | 0.103 | 0.998 | 0.080 | 0.080
X4 | 30 | 0.05 | mixed | 6.4 | 0.133 | 0.097 | 0.107 | 1.000 | 0.073 | 0.073
M5 | 30 | 0.1 | medium | 10.8 | 0.088 | 0.062 | 0.059 | 1.000 | 0.055 | 0.055
S6 | 30 | 0.4 | small | 10.9 | 0.051 | 0.043 | 0.045 | 0.998 | 0.044 | 0.044
X5 | 30 | 0.1 | mixed | 12.7 | 0.082 | 0.057 | 0.059 | 0.998 | 0.048 | 0.048
S7 | 30 | 0.5 | small | 13.6 | 0.038 | 0.034 | 0.036 | 1.000 | 0.035 | 0.035
L4 | 30 | 0.05 | large | 27.4 | 0.046 | 0.037 | 0.035 | 0.993 | 0.034 | 0.034
M6 | 30 | 0.4 | medium | 43.0 | 0.022 | 0.021 | 0.021 | 0.997 | 0.021 | 0.021
X6 | 30 | 0.4 | mixed | 50.8 | 0.022 | 0.020 | 0.020 | 0.997 | 0.020 | 0.020
M7 | 30 | 0.5 | medium | 53.8 | 0.018 | 0.017 | 0.017 | 0.999 | 0.017 | 0.017
L5 | 30 | 0.1 | large | 54.9 | 0.027 | 0.025 | 0.024 | 0.988 | 0.024 | 0.024
X7 | 30 | 0.5 | mixed | 63.5 | 0.017 | 0.016 | 0.016 | 0.997 | 0.016 | 0.016
L6 | 30 | 0.4 | large | 219.4 | 0.010 | 0.010 | 0.010 | 0.992 | 0.010 | 0.010
L7 | 30 | 0.5 | large | 274.3 | 0.008 | 0.008 | 0.008 | 0.986 | 0.008 | 0.008

“Discrete” stands for discrete likelihood methods. Scenarios are ordered by number of studies (K), and then by expected count. Bold horizontal lines separate scenarios by number of studies. White and grey shading separates scenarios with expected counts ≤1, between 1 and 5, and ≥5. We code scenarios using two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1, 6=0.4, 7=0.5).

The column “Discrete (fraction converged)” shows the proportion of simulations for which random effects methods converged successfully. Values of 1.000 mean that random effects methods converged successfully in all 1000 simulations in a scenario, and a value of e.g., 0.335 means that they converged in 335 out of 1000 simulations in a scenario. The columns “Discrete (random)” and “Discrete (hybrid)” are identical when the fraction converged is 1.000, because the random effects method was used in all simulations.

Table A-6 Comparison of coverage across random effects methods (selected scenarios with zero heterogeneity)

Scenario | K | Proportion | Sample size | Exp count | Approximate untransformed | Approximate logit | Approximate arcsine | Discrete (fraction converged) | Discrete (random) | Discrete (hybrid)
S1 | 5 | 0.001 | small | <0.1 | 1.000 | 0.000 | 1.000 | 0.168 | 0.988 | 1.000
M1 | 5 | 0.001 | medium | 0.1 | 1.000 | 0.000 | 1.000 | 0.482 | 0.977 | 1.000
S2 | 5 | 0.005 | small | 0.2 | 1.000 | 0.431 | 1.000 | 0.569 | 0.952 | 1.000
X1 | 5 | 0.001 | mixed | 0.2 | 0.998 | 0.000 | 0.650 | 0.652 | 0.972 | 0.998
S3 | 5 | 0.01 | small | 0.3 | 1.000 | 0.774 | 0.818 | 0.818 | 0.985 | 1.000
L1 | 5 | 0.001 | large | 0.6 | 1.000 | 0.847 | 0.823 | 0.956 | 0.964 | 1.000
M2 | 5 | 0.005 | medium | 0.6 | 0.999 | 0.863 | 0.815 | 0.956 | 0.965 | 0.999
X2 | 5 | 0.005 | mixed | 1.1 | 0.936 | 0.849 | 0.913 | 0.994 | 0.970 | 0.936
M3 | 5 | 0.01 | medium | 1.3 | 0.946 | 0.917 | 0.888 | 0.997 | 0.971 | 0.946
S4 | 5 | 0.05 | small | 1.7 | 0.852 | 0.931 | 0.926 | 1.000 | 0.965 | 0.852
X3 | 5 | 0.01 | mixed | 2.2 | 0.932 | 0.919 | 0.946 | 1.000 | 0.950 | 0.932
L2 | 5 | 0.005 | large | 3.2 | 0.795 | 0.954 | 0.949 | 1.000 | 0.975 | 0.795
S5 | 5 | 0.1 | small | 3.4 | 0.852 | 0.962 | 0.968 | 1.000 | 0.959 | 0.852
L3 | 5 | 0.01 | large | 6.4 | 0.875 | 0.955 | 0.950 | 1.000 | 0.960 | 0.875
M4 | 5 | 0.05 | medium | 6.4 | 0.916 | 0.956 | 0.964 | 1.000 | 0.961 | 0.916
X4 | 5 | 0.05 | mixed | 10.9 | 0.930 | 0.950 | 0.969 | 1.000 | 0.946 | 0.930
M5 | 5 | 0.1 | medium | 12.8 | 0.939 | 0.954 | 0.960 | 1.000 | 0.955 | 0.939
S6 | 5 | 0.4 | small | 13.7 | 0.956 | 0.968 | 0.960 | 1.000 | 0.965 | 0.956
S7 | 5 | 0.5 | small | 17.1 | 0.960 | 0.971 | 0.971 | 1.000 | 0.970 | 0.960
X5 | 5 | 0.1 | mixed | 21.9 | 0.935 | 0.965 | 0.975 | 1.000 | 0.949 | 0.935
L4 | 5 | 0.05 | large | 31.8 | 0.951 | 0.963 | 0.962 | 0.998 | 0.965 | 0.951
M6 | 5 | 0.4 | medium | 51.4 | 0.953 | 0.959 | 0.957 | 1.000 | 0.957 | 0.953
L5 | 5 | 0.1 | large | 63.7 | 0.954 | 0.952 | 0.954 | 1.000 | 0.952 | 0.954
M7 | 5 | 0.5 | medium | 64.2 | 0.964 | 0.964 | 0.964 | 1.000 | 0.961 | 0.964
X6 | 5 | 0.4 | mixed | 87.5 | 0.965 | 0.963 | 0.964 | 1.000 | 0.950 | 0.965
X7 | 5 | 0.5 | mixed | 109.4 | 0.971 | 0.972 | 0.972 | 1.000 | 0.958 | 0.971
L6 | 5 | 0.4 | large | 254.6 | 0.961 | 0.959 | 0.960 | 0.999 | 0.956 | 0.961
L7 | 5 | 0.5 | large | 318.3 | 0.973 | 0.973 | 0.973 | 0.998 | 0.968 | 0.973
S1 | 15 | 0.001 | small | <0.1 | 0.000 | 0.000 | 1.000 | 0.336 | 0.954 | 0.000
M1 | 15 | 0.001 | medium | 0.1 | 0.230 | 0.000 | 0.521 | 0.808 | 0.975 | 0.230
X1 | 15 | 0.001 | mixed | 0.1 | 0.954 | 0.000 | 0.665 | 0.864 | 0.949 | 0.954
S2 | 15 | 0.005 | small | 0.1 | 0.761 | 0.000 | 0.585 | 0.875 | 0.955 | 0.761
S3 | 15 | 0.01 | small | 0.3 | 0.988 | 0.018 | 0.481 | 0.982 | 0.965 | 0.988
M2 | 15 | 0.005 | medium | 0.6 | 0.999 | 0.490 | 0.606 | 0.999 | 0.975 | 0.999
L1 | 15 | 0.001 | large | 0.6 | 0.999 | 0.498 | 0.592 | 1.000 | 0.978 | 0.999
X2 | 15 | 0.005 | mixed | 0.7 | 0.909 | 0.301 | 0.725 | 1.000 | 0.970 | 0.909
M3 | 15 | 0.01 | medium | 1.1 | 0.869 | 0.726 | 0.772 | 0.999 | 0.968 | 0.869
X3 | 15 | 0.01 | mixed | 1.3 | 0.851 | 0.688 | 0.802 | 1.000 | 0.950 | 0.851
S4 | 15 | 0.05 | small | 1.4 | 0.686 | 0.782 | 0.823 | 1.000 | 0.955 | 0.686
S5 | 15 | 0.1 | small | 2.7 | 0.642 | 0.890 | 0.925 | 1.000 | 0.966 | 0.642
L2 | 15 | 0.005 | large | 3.1 | 0.578 | 0.875 | 0.907 | 0.999 | 0.964 | 0.578
M4 | 15 | 0.05 | medium | 5.7 | 0.746 | 0.912 | 0.942 | 1.000 | 0.957 | 0.746
L3 | 15 | 0.01 | large | 6.3 | 0.743 | 0.924 | 0.952 | 0.999 | 0.971 | 0.743
X4 | 15 | 0.05 | mixed | 6.7 | 0.760 | 0.927 | 0.928 | 0.999 | 0.960 | 0.760
S6 | 15 | 0.4 | small | 10.8 | 0.948 | 0.960 | 0.955 | 0.998 | 0.957 | 0.948
M5 | 15 | 0.1 | medium | 11.5 | 0.882 | 0.945 | 0.950 | 0.999 | 0.954 | 0.882
X5 | 15 | 0.1 | mixed | 13.4 | 0.861 | 0.941 | 0.958 | 1.000 | 0.956 | 0.861
S7 | 15 | 0.5 | small | 13.5 | 0.943 | 0.964 | 0.960 | 1.000 | 0.957 | 0.943
L4 | 15 | 0.05 | large | 31.4 | 0.924 | 0.957 | 0.950 | 0.994 | 0.956 | 0.924
M6 | 15 | 0.4 | medium | 45.9 | 0.972 | 0.969 | 0.968 | 0.997 | 0.967 | 0.972
X6 | 15 | 0.4 | mixed | 53.5 | 0.950 | 0.957 | 0.955 | 0.998 | 0.953 | 0.950
M7 | 15 | 0.5 | medium | 57.4 | 0.958 | 0.960 | 0.959 | 0.996 | 0.958 | 0.958
L5 | 15 | 0.1 | large | 62.8 | 0.949 | 0.963 | 0.964 | 0.993 | 0.965 | 0.949
X7 | 15 | 0.5 | mixed | 66.9 | 0.966 | 0.965 | 0.963 | 0.999 | 0.959 | 0.966
L6 | 15 | 0.4 | large | 251.4 | 0.958 | 0.955 | 0.958 | 0.996 | 0.955 | 0.958
L7 | 15 | 0.5 | large | 314.2 | 0.963 | 0.964 | 0.963 | 0.985 | 0.962 | 0.963
S1 | 30 | 0.001 | small | <0.1 | 0.000 | 0.000 | 1.000 | 0.537 | 0.989 | 0.000
M1 | 30 | 0.001 | medium | 0.1 | 0.000 | 0.000 | 0.254 | 0.949 | 0.966 | 0.000
X1 | 30 | 0.001 | mixed | 0.1 | 0.846 | 0.000 | 0.429 | 0.979 | 0.959 | 0.846
S2 | 30 | 0.005 | small | 0.1 | 0.000 | 0.000 | 0.227 | 0.983 | 0.977 | 0.000
S3 | 30 | 0.01 | small | 0.3 | 0.822 | 0.000 | 0.226 | 1.000 | 0.964 | 0.822
M2 | 30 | 0.005 | medium | 0.5 | 1.000 | 0.106 | 0.308 | 1.000 | 0.975 | 1.000
L1 | 30 | 0.001 | large | 0.5 | 1.000 | 0.092 | 0.331 | 1.000 | 0.972 | 1.000
X2 | 30 | 0.005 | mixed | 0.6 | 0.906 | 0.003 | 0.479 | 1.000 | 0.957 | 0.906
M3 | 30 | 0.01 | medium | 1.1 | 0.754 | 0.445 | 0.544 | 0.998 | 0.953 | 0.754
X3 | 30 | 0.01 | mixed | 1.3 | 0.701 | 0.278 | 0.659 | 0.998 | 0.962 | 0.701
S4 | 30 | 0.05 | small | 1.4 | 0.449 | 0.556 | 0.661 | 1.000 | 0.963 | 0.449
S5 | 30 | 0.1 | small | 2.7 | 0.381 | 0.754 | 0.881 | 0.999 | 0.956 | 0.381
L2 | 30 | 0.005 | large | 2.7 | 0.274 | 0.686 | 0.840 | 1.000 | 0.968 | 0.274
M4 | 30 | 0.05 | medium | 5.4 | 0.512 | 0.839 | 0.916 | 0.999 | 0.959 | 0.512
L3 | 30 | 0.01 | large | 5.5 | 0.458 | 0.857 | 0.914 | 0.998 | 0.957 | 0.458
X4 | 30 | 0.05 | mixed | 6.4 | 0.652 | 0.881 | 0.901 | 1.000 | 0.950 | 0.652
M5 | 30 | 0.1 | medium | 10.8 | 0.750 | 0.911 | 0.944 | 1.000 | 0.951 | 0.750
S6 | 30 | 0.4 | small | 10.9 | 0.926 | 0.958 | 0.957 | 0.998 | 0.957 | 0.926
X5 | 30 | 0.1 | mixed | 12.7 | 0.785 | 0.920 | 0.960 | 0.998 | 0.971 | 0.785
S7 | 30 | 0.5 | small | 13.6 | 0.949 | 0.964 | 0.961 | 1.000 | 0.960 | 0.949
L4 | 30 | 0.05 | large | 27.4 | 0.885 | 0.938 | 0.956 | 0.993 | 0.954 | 0.885
M6 | 30 | 0.4 | medium | 43.0 | 0.958 | 0.968 | 0.967 | 0.997 | 0.965 | 0.958
X6 | 30 | 0.4 | mixed | 50.8 | 0.958 | 0.959 | 0.962 | 0.997 | 0.959 | 0.958
M7 | 30 | 0.5 | medium | 53.8 | 0.950 | 0.956 | 0.951 | 0.999 | 0.952 | 0.950
L5 | 30 | 0.1 | large | 54.9 | 0.916 | 0.953 | 0.958 | 0.988 | 0.955 | 0.916
X7 | 30 | 0.5 | mixed | 63.5 | 0.964 | 0.958 | 0.963 | 0.997 | 0.959 | 0.964
L6 | 30 | 0.4 | large | 219.4 | 0.954 | 0.954 | 0.956 | 0.992 | 0.954 | 0.954
L7 | 30 | 0.5 | large | 274.3 | 0.948 | 0.948 | 0.948 | 0.986 | 0.949 | 0.948

“Discrete” stands for discrete likelihood methods. Scenarios are ordered by number of studies (K), and then by expected count. Bold horizontal lines separate scenarios by number of studies. White and grey shading separates scenarios with expected counts ≤1, between 1 and 5, and ≥5. We code scenarios using two characters, a letter (indicating sample size scenarios; S=small, M=medium, L=large, X=mixed); and a number (indicating the true proportions; 1=0.001, 2=0.005, 3=0.01, 4=0.05, 5=0.1, 6=0.4, 7=0.5). The column “Discrete (fraction converged)” shows the proportion of simulations for which random effects methods converged successfully. Values of 1.000 mean that random effects methods converged successfully in all 1000 simulations in a scenario, and a value of e.g., 0.335 means that they converged in 335 out of 1000 simulations in a scenario. The columns “Discrete (random)” and “Discrete (hybrid)” are identical when the fraction converged is 1.000, because the random effects method was used in all simulations.