# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CER: Comparative Effectiveness Review
EPC: Evidence based Practice Center
GLMM: generalized linear mixed models
RCT: Randomized controlled trial